# 1 INTRODUCTION

Dibenzothiophene (CASRN 132-65-0) is a solid, sulfur-containing, three-ringed, heterocyclic polycyclic aromatic hydrocarbon (PAH) derivative. It is one of the organosulfur components of petroleum and coal and is used as a chemical intermediate and as an ingredient in cosmetics and pharmaceuticals (NLM, 2021b; Blümer et al., 2011; Deutschmann et al., 2011). Dibenzothiophene is listed as an active substance in commerce on the public Toxic Substances Control Act (TSCA) inventory (U.S. EPA, 2021e) and it is registered with Europe’s Registration, Evaluation, Authorization, and Restriction of Chemicals (REACH) program (ECHA, 2021).

Production and import volumes were not reported in U.S. EPA’s Chemical Data Reporting (CDR) database (U.S. EPA, 2021a). No public information on industrial production or synthetic processes were located.

The empirical formula for dibenzothiophene is C_12_H_8_S; its structure is shown in Figure 1. Experimental and estimated physicochemical properties identified for dibenzothiophene from U.S. EPA (2021c) and NLM (2021b) are presented in Table 1. When more than one experimental value was available, an experimental average is presented. Dibenzothiophene is moderately volatile from water and moist soil surfaces based on its calculated Henry’s law constant; the soil adsorption coefficient indicates that dibenzothiophene will strongly sorb to soil and sediment, however, which may limit volatilization from these surfaces. Due to strong sorption and low water solubility, the potential to leach to groundwater or undergo runoff after precipitation is low.

Figure 1 Dibenzothiophene (CASRN 132-65-0) Structure

Shape, Polygon Dibenzothiophene Structure

Table 1 Physicochemical Properties of Dibenzothiophene (CASRN 132-65-0)

Property (unit) | Value^a^
Physical state | Solid^b^
Boiling point (°C) | 333
Melting point (°C) | 97.0
Density (g/cm^3^) | 1.23–1.25 (estimated)
Vapor pressure (mm Hg at 25°C) | 0.000205 (extrapolated)^b^
pH (unitless) | NA
pKa (unitless) | NA
Solubility in water (mg/L at 25°C) | 1.47 (converted from PhysProp NCCT value of 7.98 × 10^−6^ mol/L)
Log octanol/water partition coefficient (log K_ow_) | 4.38
Henry’s law constant (atm-m^3^/mole at 25°C) | 3.38 × 10^−5^ (calculated from vapor pressure/water solubility)^c^
Soil adsorption coefficient K_oc_ (units not reported) | 5,273–20,535^b^
Atmospheric OH rate constant (cm^3^/molecule-sec at 25°C) | 8.10 × 10^−12 b^
Atmospheric half-life (d) | 1.3 (estimated using 12-h day; 1.5 × 10^6^ OH/cm^3^)^d^
Relative vapor density (air = 1) | Not applicable for solid
Molecular weight (g/mol) | 184.26
Flash point (°C) | Not applicable for solid

a Unless otherwise noted, values are from U.S. EPA (2021c).

b NLM (2021b).

c U.S. EPA (2012); calculated by EPI Suite™ using a vapor pressure of 0.000205 mm Hg and a water solubility of 1.47 mg/L.

d U.S. EPA (2012).

EPI Suite™ = Estimation Programs Interface Suite; NA = not applicable; NCCT = National Center for Computational Toxicology; PhysProp = Physical Properties Database.

A summary of available toxicity values for dibenzothiophene from U.S. EPA and other agencies/organizations is provided in Table 2.

Table 2 Summary of Available Toxicity Values for Dibenzothiophene (CASRN 132-65-0)

Source (parameter)^a,b^ | Value (applicability) | Notes | Reference
Noncancer
IRIS | NV | NA | U.S. EPA (2021d)
HEAST | NV | NA | U.S. EPA (2011b)
DWSHA | NV | NA | U.S. EPA (2018)
ATSDR | NV | NA | ATSDR (2021)
WHO | NV | NA | WHO (2021)
CalEPA | NV | NA | CalEPA (2021, 2020)
OSHA | NV | NA | OSHA (2021a, 2021b, 2021c)
NIOSH | NV | NA | NIOSH (2018)
ACGIH | NV | NA | ACGIH (2020)
Cancer
IRIS | NV | NA | U.S. EPA (2021d)
HEAST | NV | NA | U.S. EPA (2011b)
DWSHA | NV | NA | U.S. EPA (2018)
NTP | NV | NA | NTP (2016)
IARC (WOE) | Group 3: not classifiable as to its carcinogenicity to humans | Based on inadequate evidence for carcinogenicity in experimental animals and no available data for carcinogenicity in humans. | IARC (2013)
CalEPA | NV | NA | CalEPA (2021, 2020)
ACGIH | NV | NA | ACGIH (2020)

a Sources: ACGIH = American Conference of Governmental Industrial Hygienists; ATSDR = Agency for Toxic Substances and Disease Registry; CalEPA = California Environmental Protection Agency; DWSHA = Drinking Water Standards and Health Advisories; HEAST = Health Effects Assessment Summary Tables; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; WHO = World Health Organization.

b Parameters: WOE = weight of evidence.

NA = not applicable; NV = not available.

Literature searches were conducted in June 2019 and updated in June 2022 for studies relevant to the derivation of provisional toxicity values for dibenzothiophene. Searches were conducted using U.S. EPA’s Health and Environmental Research Online (HERO) database of scientific literature. HERO searches the following databases: PubMed, TOXLINE^1^ (including TSCATS1), and Web of Science. The following resources were searched outside of HERO for health-related values: American Conference of Governmental Industrial Hygienists (ACGIH), Agency for Toxic Substances and Disease Registry (ATSDR), California Environmental Protection Agency (CalEPA), Defense Technical Information Center (DTIC), European Centre for Ecotoxicology and Toxicology of Chemicals (ECETOC), European Chemicals Agency (ECHA), U.S. EPA Chemical Data Access Tool (CDAT), U.S. EPA ChemView, U.S. EPA Integrated Risk Information System (IRIS), U.S. EPA Health Effects Assessment Summary Tables (HEAST), U.S. EPA Office of Water (OW), International Agency for Research on Cancer (IARC), U.S. EPA TSCATS2/TSCATS8e, U.S. EPA High Production Volume (HPV), Chemicals via International Programme on Chemical Safety (IPCS) INCHEM, Japan Existing Chemical Data Base (JECDB), Organisation for Economic Co-operation and Development (OECD) Screening Information Data Sets (SIDS), OECD International Uniform Chemical Information Database (IUCLID), OECD HPV, National Institute for Occupational Safety and Health (NIOSH), National Toxicology Program (NTP), Occupational Safety and Health Administration (OSHA), and World Health Organization (WHO).

1 Note that this version of TOXLINE is no longer updated (https://www.nlm.nih.gov/databases/download/toxlinesubset.html); therefore, it was not included in the literature search update from June 2022.