# APPENDIX D REFERENCES

ACGIH (American Conference of Governmental Industrial Hygienists). (2020). 2020 TLVs and BEIs: Based on the documentation of the threshold limit values for chemical substances and physical agents & biological exposure indices. Cincinnati, OH.
Amat A; Pfohl-Leszkowicz A; Castegnaro M. (2004). Genotoxic activity of thiophenes on liver human cell line (HepG2). Polycycl Aromat Compd 24: 733–742. 10.1080/10406630490472473
ATSDR (Agency for Toxic Substances and Disease Registry). (2021). Toxic substances portal: Toxicological profiles [Database]. Atlanta, GA. Retrieved from https://www.atsdr.cdc.gov/toxprofiledocs/index.html
Blümer GP; Collin G; Höke H. (2011). Tar and pitch. In Ullmann's encyclopedia of industrial chemistry. Online: John Wiley & Sons. 10.1002/14356007.a26_091.pub2
Brinkmann M; Blenkle H; Salowsky H; Bluhm K; Schiwy S; Tiehm A; Hollert H. (2014). Genotoxicity of heterocyclic PAHs in the micronucleus assay with the fish liver cell line RTL-W1. PLoS ONE 9: e85692. 10.1371/journal.pone.0085692 24416442
CalEPA (California Environmental Protection Agency). (2020). Consolidated table of OEHHA/CARB approved risk assessment health values. Sacramento, California. https://ww2.arb.ca.gov/resources/documents/consolidated-table-oehha-carb-approved-risk-assessment-health-values
CalEPA (California Environmental Protection Agency). (2021). OEHHA chemical database [Database]. Sacramento, CA: Office of Environmental Health Hazard Assessment. Retrieved from https://oehha.ca.gov/chemicals
Chaudhury S; Khan S; Rahimtula AD. (1988). Comparison of the inhibitory effects of some compounds present in crude oils on rat platelet aggregation: Role of intra- and extra-cellular calcium. Toxicology 51: 35–46. 10.1016/0300-483X(88)90078-9 3413799
ChemIDplus. (2021). ChemIDplus advanced. Available online at https://chem.nlm.nih.gov/chemidplus/
Davis AP; Grondin CJ; Johnson RJ; Sciaky D; Wiegers J; Wiegers TC; Mattingly CJ. (2021). The comparative toxicogenomics database (CTD): update 2021 [Database]: MDI Biological Laboratory. NC State University. Retrieved from http://ctdbase.org/
Deutschmann O; Knözinger H; Kochloefl K; Turek T. (2011). Heterogeneous catalysis and solid catalysts. 3. Industrial applications. In Ullmann's encyclopedia of industrial chemistry. Online: John Wiley & Sons. 10.1002/14356007.o05_o03
Dickson JG; Adams VD. (1980). Evaluation of mutagenicity testing of extracts from processed oil shale (pp. 52 PP). (UWRL/Q-80/01). Logan, Utah: Utah Water Research Laboratory, Utah State University.
ECHA (European Chemicals Agency). (2021). Substance infocard: Dibenzothiophene. Available online at https://echa.europa.eu/substance-information/-/substanceinfo/100.004.613 (accessed June 22, 2021).
Hard GC; Alden CL; Bruner RH; Frith CH; Lewis RM; Owen RA; Krieg K; Durchfield-Meyer B. (1999). Non-proliferative lesions of the kidney and lower urinary tract in rats. In Guides for Toxicologic Pathology. Washington, D.C.: STP/ARP/AFIP.
IARC (International Agency for Research on Cancer). (2013). Bitumens and bitumen emissions, and some N- and S-heterocyclic polycyclic aromatic hydrocarbons [IARC Monograph]. Lyon, France. https://publications.iarc.fr/Book-And-Report-Series/Iarc-Monographs-On-The-Identification-Of-Carcinogenic-Hazards-To-Humans/Bitumens-And-Bitumen-Emissions-And-Some-Em-N-Em---And-Em-S-Em--Heterocyclic-Polycyclic-Aromatic-Hydrocarbons-2013
Jacob J; Schmoldt A; Augustin C; Raab G; Grimmer G. (1991). Rat liver microsomal ring-oxidation and s-oxidation of thiaarenes with central or peripheral thiophene rings. Toxicology 68: 181–194. 10.1016/0300-483X(91)90020-2 1891783
JECDB (Japan Existing Chemical Data Base). (2010a). Dibenzothiophene [CAS no. 132–65-0]: Bacterial reverse mutation test. (SR05343). Japanese National Institute of Health Sciences.
JECDB (Japan Existing Chemical Data Base). (2010b). Dibenzothiophene [CAS no. 132–65-0]: In vitro mammalian chromosome aberration test. (SR05342). Japanese National Institute of Health Sciences.
JECDB (Japan Existing Chemical Data Base). (2011). [Dibenzothiophene [CAS no. 132–65-0]: Repeated dose 28-day oral toxicity study]. (SR05343). Japanese National Institute of Health Sciences. https://dra4.nihs.go.jp/mhlw_data/home/pdf/PDF132-65-0b.pdf
Leighton FA. (1989). Acute oral toxicity of dibenzothiophene for male CD-1 mice: LD50, lesions, and the effect of preinduction of mixed-function oxidases. Fundam Appl Toxicol 12: 787–792. 10.1016/0272-0590(89)90010-9 2744279
Madill RE A; Brownlee BG; Josephy PD; Bunce NJ. (1999). Comparison of the Ames Salmonella assay and Mutatox genotoxicity assay for assessing the mutagenicity of polycyclic aromatic compounds in porewater from Athabasca oil sands mature fine tailings. Environ Sci Technol 33: 2510–2516. 10.1021/es981343o
Mcfall T; Booth GM; Lee ML; Tominaga Y; Pratap R; Castle RN; Tedjamulia M. (1984). Mutagenic activity of methyl-substituted tricyclic and tetracyclic aromatic sulfur heterocycles. Mutat Res Genet Toxicol 135: 97–103. 10.1016/0165-1218(84)90161-7
NIOSH (National Institute for Occupational Safety and Health). (2018). NIOSH pocket guide to chemical hazards. Index of chemical abstracts service registry numbers (CAS No.). Atlanta, GA. http://www.cdc.gov/niosh/npg/npgdcas.html
NLM (National Library of Medicine). (2021a). ChemIDplus: Dibenzothiophene. Available online at https://chem.nlm.nih.gov/chemidplus/name/dibenzothiophene
NLM (National Library of Medicine). (2021b). PubChem: Dibenzothiophene [CAS No. 132–65-0]. Available online at https://pubchem.ncbi.nlm.nih.gov/compound/3023
NTP (National Toxicology Program). (2016). 14th Report on carcinogens. Research Triangle Park, NC. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html
OECD (Organisation for Economic Co-operation and Development). (2020). The OECD QSAR toolbox [version 4.4.1]: Dibenzothiophene (CASRN: 132–65-0) [Database]. Retrieved from http://www.oecd.org/chemicalsafety/risk-assessment/oecd-qsar-toolbox.htm
OECD (Organisation for Economic Co-operation and Development). (2021). The OECD QSAR toolbox [version 4.5] [Database]. Retrieved from http://www.oecd.org/chemicalsafety/risk-assessment/oecd-qsar-toolbox.htm
OSHA (Occupational Safety & Health Administration). (2021a). Air contaminants: Occupational safety and health standards for shipyard employment, subpart Z, toxic and hazardous substances. (OSHA Standard 1915.1000). Washington, DC. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000
OSHA (Occupational Safety & Health Administration). (2021b). Safety and health regulations for construction: Occupational health and environmental controls: Gases, vapors, fumes, dusts, and mists. Washington, DC. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55
OSHA (Occupational Safety & Health Administration). (2021c). Table Z-1: Limits for air contaminants. Occupational safety and health standards, subpart Z, toxic and hazardous substances. Washington, DC. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1
Pelroy RA; Stewart DL; Tominaga Y; Iwao M; Castle RN; Lee ML. (1983). Microbial mutagenicity of 3- and 4-ring polycyclic aromatic sulfur heterocycles. Mutat Res 117: 31–40. 10.1016/0165-1218(83)90150-7 6188045
Peters JM; Boyd EM. (1966). Organ weights and water levels of the rat following reduced food intake. J Nutr 90: 354–360.5954817
Rasmussen K; Booth GM; Lee ML; Castle RN. (1991). Mutagenicities of hydroxy-substituted carbazoles and dibenzothiophenes using the CHO HGPRT assay. Environ Toxicol Chem 10: 1133–1137. 10.1002/etc.5620100904
Sarma SN; Blais JM; Chan HM. (2017). Neurotoxicity of alkylated polycyclic aromatic compounds in human neuroblastoma cells. J Toxicol Environ Health A 80: 285–300. 10.1080/15287394.2017.1314840 28598261
Silva KT; Oliveira-Castro RA; Rodrigues VC; de Lima WG; Rodrigues CV; Castro-Borges W; Guerra Andrade MH. (2015). DBT- and DBTO2-induced dysplasia and their associated proteomic alterations in the small intestines of Wistar rats. J Proteome Res 14: 385–396. 10.1021/pr5009459 25369245
Thomas JO; Deeds F; Cox AJ. (1942). Chronic toxicity of diphenylene sulfide to the albino rat. J Food Sci 7: 161–169. 10.1111/j.1365-2621.1942.tb17244.x
U.S. EPA (U.S. Environmental Protection Agency). (1988). Recommendations for and documentation of biological values for use in risk assessment [EPA Report]. (EPA600687008). Cincinnati, OH. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=34855
U.S. EPA (U.S. Environmental Protection Agency). (1991). Alpha-2u-globulin: Association with chemically induced renal toxicity and neoplasia in the male rat. (EPA625391019F. PB92143668). Washington, DC: U.S. Environmental Protection Agency, National Center for Environmental Assessment. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=PB92143668
U.S. EPA (U.S. Environmental Protection Agency). (2002). A review of the reference dose and reference concentration processes. (EPA630P02002F). Washington, DC. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2005). Guidelines for carcinogen risk assessment [EPA Report]. (EPA630P03001F). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3-25-05.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2011a). Chemical assessment clustering engine (ChemACE). Retrieved from https://www.epa.gov/tsca-screening-tools/chemicalassessment-clustering-engine-chemace
U.S. EPA (U.S. Environmental Protection Agency). (2011b). Health effects assessment summary tables (HEAST) for superfund [EPA Report]. Washington, DC. https://epaheast.ornl.gov/heast.php
U.S. EPA (U.S. Environmental Protection Agency). (2011c). Recommended use of body weight 3/4 as the default method in derivation of the oral reference dose. (EPA100R110001). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/recommended-use-of-bw34.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2012). Estimation Programs Interface Suite™ (EPISuite) for Microsoft® Windows, v 4.11: Dibenzothiophene [CAS No. 132–65-0] [Fact Sheet]. Washington, DC. https://www.epa.gov/tsca-screening-tools/episuitetm-estimation-program-interface
U.S. EPA (U.S. Environmental Protection Agency). (2018). 2018 Edition of the drinking water standards and health advisories tables [EPA Report]. (EPA822F18001). Washington, DC: U.S. Environmental Protection Agency, Office of Water. https://www.epa.gov/system/files/documents/2022-01/dwtable2018.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2021a). Chemical data reporting: Dibenzothiophene [CAS No. 132–65-0]. Retrieved from https://chemview.epa.gov/chemview
U.S. EPA (U.S. Environmental Protection Agency). (2021b). CompTox chemicals dashboard. Washington, DC. Retrieved from https://comptox.epa.gov/dashboard
U.S. EPA (U.S. Environmental Protection Agency). (2021c). CompTox chemicals dashboard: Dibenzothiophene 132–65-0. https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID0047741#details
U.S. EPA (U.S. Environmental Protection Agency). (2021d). Integrated risk information system (IRIS) database [Database]. Washington, DC. Retrieved from http://www.epa.gov/iris/
U.S. EPA (U.S. Environmental Protection Agency). (2021e). Non-confidential TSCA inventory: Dibenzothiophene [CAS No. 132–65-0]. Retrieved from https://www.epa.gov/tscainventory/how-access-tsca-inventory#download
Vignier V; Berthou F; Dreano Y; Floch HH. (1985). Dibenzothiophene sulphoxidation: A new and fast high-performance liquid chromatographic assay of mixed-function oxidation. Xenobiotica 15: 991–999. 10.3109/00498258509049094 4090531
Wang NC; Zhao QJ; Wesselkamper SC; Lambert JC; Petersen D; Hess-Wilson JK. (2012). Application of computational toxicological approaches in human health risk assessment. I. A tiered surrogate approach. Regul Toxicol Pharmacol 63: 10–19. 10.1016/j.yrtph.2012.02.006 22369873
WHO (World Health Organization). (2021). Online catalog for the Environmental Health Criteria (EHC) monographs [Database]. Geneva, Switzerland: World Health Organization (WHO). Retrieved from http://www.who.int/ipcs/publications/ehc/en/
Wilson RH; McNaught JB; Deeds F. (1938). Chronic nicotine toxicity IV. Effect of nicotine-containing diets on histology and weights of organs of albino rats. J Ind Hyg Toxicol 20: 468–481.