# APPENDIX C BENCHMARK DOSE MODELING RESULTS

## MODELING PROCEDURE FOR DICHOTOMOUS DATA

The benchmark dose (BMD) modeling of dichotomous data was conducted with the U.S. Environmental Protection Agency (U.S. EPA) Benchmark Dose Software (BMDS; version 3.2). For these data, the Gamma, Logistic, Log-Logistic, Probit, Log-Probit, Hill, Multistage, and Weibull dichotomous models available within the software were fit using a benchmark response (BMR) of 10% extra risk. In general, the BMR should be near the low end of the observable range of increased risk in the study. BMRs that are too low can result in widely disparate benchmark dose lower confidence limit (BMDL) estimates from different models (high model dependence). Adequacy of model fit is judged based on the χ2 goodness-of-fit p-value (p > 0.1), magnitude of scaled residuals (absolute value <2.0), and visual inspection of the model fit. Among all models providing adequate fit, the BMDL from the model with the lowest Akaike’s information criterion (AIC) is selected as a potential point of departure (POD), if the BMDLs are sufficiently close (less than approximately threefold); if the BMDLs are not sufficiently close (greater than approximately threefold), model dependence is indicated, and the model with the lowest reliable BMDL is selected.

## MODELING PROCEDURE CONTINUOUS DATA MODELING

The BMD modeling of continuous data was conducted with the U.S. EPA BMDS (version 3.2). For these data, the Exponential, Linear, Polynomial, and Power continuous models available within the software were used. The continuous Hill model was not considered for the derivation of a POD because it has five parameters and requires a data set with a minimum of six data points (including control). The continuous models available within the software were fit using a BMR of 1 standard deviation (SD) or alternative BMRs where appropriate as outlined in the Benchmark Dose Technical Guidance (U.S. EPA, 2012). A BMR 10% relative deviation (RD) for liver and kidney weights is considered a minimally biologically significant response in adult animals and was applied in this assessment for benchmark dose (BMD) modeling purposes. An adequate fit was judged based on the χ2 goodness-of-fit p-value (p > 0.1), magnitude of the scaled residuals in the vicinity of the BMR, and visual inspection of the model fit. In addition to these three criteria for judging adequacy of model fit, a determination was made as to whether the variance across dose groups was constant. If a constant variance model was deemed appropriate based on the statistical test provided in BMDS (i.e., Test 2; p-value > 0.1), the final BMD results were estimated from a constant variance model. If the test for homogeneity of variance was rejected (p-value < 0.1), the model was run again while modeling the variance as a power function of the mean to account for this nonconstant variance. If this nonconstant variance model did not adequately fit the data (i.e., Test 3; p-value < 0.1), the data set was considered unsuitable for BMD modeling. Among all models providing adequate fit, the lowest BMDL has been selected if the BMDLs estimated from different models varied more than threefold; otherwise, the BMDL from the model with the lowest AIC has been selected as a potential POD from which to derive the proposed reference value.

## BMD MODELING TO IDENTIFY POTENTIAL PODS FOR DERIVATION OF A SCREENING SUBCHRONIC PROVISIONAL REFERENCE DOSE

### Increased Relative Liver Weight in Male Sprague Dawley Rats After Oral Treatment with Dibenzothiophene for 28 Days (JECDB, 2011)

The procedure outlined above for continuous data was applied to the data for increased relative liver weight in male Sprague Dawley rats orally exposed to dibenzothiophene for 28 days (JECDB, 2011). The constant variance model provided an adequate fit to the variance data, and the Exponential models 2 and 3, and the Linear model provided adequate fit to the means. Visual inspection of the dose-response curves suggested adequate fit, BMDLs were not 10 times lower than the lowest nonzero dose, and scaled residuals did not exceed ±2 units at the data point closest to the predefined BMR. BMDLs for models providing adequate fit were sufficiently close (differed by less than threefold), so the model with the lowest AIC was selected (Exponential model 3). The estimated human equivalent benchmark dose associated with 10% relative deviation from the control (BMD_0.1RD_) and benchmark dose lower confidence limit associated with 10% relative deviation from the control (BMDL_0.1RD_) values of 2.33 and 2.01 mg/kg-day, respectively, were selected from this model. The results of the BMD modeling are summarized in Table C-1. Figure C-1 shows the fit of the Exponential model 3 model to the data.

Table C-1 BMD Modeling Results (Constant Variance) for Relative Liver Weight in Male Sprague Dawley Rats Orally Exposed to Dibenzothiophene for 28 Days^a^

Model | Variance p-Value^b^ | Means p-Value^b^ | Scaled Residual at Dose Nearest BMD | AIC | BMD_0.1RD_ (HED, (mg/kg-d) | BMDL_0.1RD_ (HED, (mg/kg-d)
Exponential (model 2)^c^ | 0.56101604 | 0.2269728 | −0.767558354 | 0.935991293 | 2.330715 | 2.011481
Exponential (model 3) ^c^ ^,^ ^d^ | 0.56101604 | 0.226973 | −0.767697226 | 0.935989576 | 2.330708 | 2.011754
Exponential (model 4)^c^ | 0.56101604 | 0.0691553 | −1.045102633 | 3.273097499 | 2.071878 | 1.36167
Exponential (model 5)^c^ | 0.56101604 | NA | −1.042495246 | 5.26907005 | 2.07426 | 1.362246
Polynomial (3-degree)^e^ | 0.56101604 | 0.0985958 | −0.429504946 | 2.698252338 | 1.771026 | 4.6872224
Polynomial (2-degree)^e^ | 0.56101604 | 0.0890464 | −0.53754105 | 2.861669325 | 1.761492 | 4.2908893
Power^c^ | 0.56101604 | 0.0737363 | −0.763984146 | 3.167966089 | 1.743172 | 4.5119764
Linear^e^ | 0.56101604 | 0.1921587 | −1.042667628 | 1.269007639 | 1.737413 | 2.5442898

a JECDB (2011).

b Values <0.10 fail to meet conventional goodness-of-fit criteria.

c Power restricted to be ≥1.

d Selected model.

e Coefficients restricted to be positive.

AIC = Akaike’s information criterion; BMD = benchmark dose; BMDL = lower confidence limit on the BMD (subscripts denote BMR: i.e., 0.1RD = dose associated with 10% relative deviation from the control); BMR = benchmark response; NA = test for fit is not valid; HED = human equivalent dose.

Figure C-1 Fit of Exponential Model 3 to Data for Relative Liver Weight in Male Sprague Dawley Rats Exposed to Dibenzothiophene for 28 Days (JECDB, 2011)

Figure shows the fit of exponential model 3 to data. Fit of Exponential Model 3 to Data for Relative Liver Weight in Male Sprague Dawley Rats Exposed to Dibenzothiophene for 28 Days.

BMD Model Output for Figure C-1

### Increased Relative Liver Weight in Female Sprague Dawley Rats After Oral Treatment with Dibenzothiophene for 28 Days (JECDB, 2011)

The procedure outlined above for continuous data was applied to the data for increased relative liver weight in female Sprague Dawley rats orally exposed to dibenzothiophene for 28 days (JECDB, 2011). The constant variance model provided an adequate fit to the variance data and all models provided adequate fit to the means. Visual inspection of the dose-response curves suggested adequate fit, BMDLs were not 10 times lower than the lowest nonzero dose, and scaled residuals did not exceed ±2 units at the data point closest to the predefined BMR. BMDLs for models providing adequate fit were sufficiently close (differed by less than threefold), so the model with the lowest AIC was selected (Linear). The Polynomial and Power models converged to the Linear model. The Linear model estimated human equivalent BMD_0.1RD_ and BMDL_0.1RD_ values of 2.73 and 2.19 mg/kg-day, respectively. The results of the BMD modeling are summarized in Table C-2. Figure C-2 shows the fit of the Linear model to the data.

Table C-2 BMD Modeling Results (Constant Variance) for Relative Liver Weight in Female Sprague Dawley Rats Orally Exposed to Dibenzothiophene for 28 Days^a^

Model | Variance p-Value^b^ | Means p-Value^b^ | Scaled Residual at Dose Nearest BMD | AIC | BMD_0.1RD_ (HED, (mg/kg-d) | BMDL_0.1RD_ (HED, (mg/kg-d)
Exponential (model 2)^c^ | 0.27880585 | 0.354743 | 0.121794767 | −3.39315347 | 2.94462 | 2.417078
Exponential (model 3)^c^ | 0.27880585 | 0.3547431 | 0.121823756 | −3.393153703 | 2.944643 | 2.419279
Exponential (model 4)^c^ | 0.27880585 | 0.2060485 | −0.451460518 | −1.866901424 | 2.210648 | 1.105419
Exponential (model 5)^c^ | 0.27880585 | 0.2060467 | −0.45428488 | −1.866889072 | 2.20753 | 1.105422
Polynomial (3-degree)^d^ | 0.27880585 | 0.3935635 | −0.021131946 | −3.600850872 | 2.733293 | 2.185768
Polynomial (2-degree)^d^ | 0.27880585 | 0.3935635 | −0.021131946 | −3.600850872 | 2.733293 | 2.185768
Power^c^ | 0.27880585 | 0.3935635 | −0.02113139 | −3.600850872 | 2.733292 | 2.185999
Linear ^d^ ^,^ ^e^ | 0.27880585 | 0.3935635 | −0.021131734 | −3.600850872 | 2.733293 | 2.185768

a JECDB (2011).

b Values <0.10 fail to meet conventional goodness-of-fit criteria.

c Power restricted to be ≥1.

d Coefficients restricted to be positive.

e Selected model.

AIC = Akaike’s information criterion; BMD = benchmark dose; BMDL = lower confidence limit on the BMD (subscripts denote BMR: i.e., 0.1RD = dose associated with 10% relative deviation from the control); BMR = benchmark response; HED = human equivalent dose.

Figure C-2 Fit of Linear Model to Data for Relative Liver Weight in Female Sprague Dawley Rats Exposed to Dibenzothiophene for 28 Days (JECDB, 2011)

Figure shows the fit of linear model to data. Fit of Linear Model to Data for Relative Liver Weight in Female Sprague Dawley Rats Exposed to Dibenzothiophene for 28 Days.

BMD Model Output for Figure C-2

### Increased Hepatocyte Hypertrophy in Female Sprague Dawley Rats After Oral Treatment with Dibenzothiophene for 28 Days (JECDB, 2011)

The procedure outlined above for dichotomous data was applied to the data for increased hepatocyte hypertrophy in female Sprague Dawley rats orally exposed to dibenzothiophene for 28 days (JECDB, 2011). All models provided adequate fit (p-value > 0.10). However, based on visual inspection, the Multistage degree 1 model was not found to have an adequate fit (estimated probabilities consistently misrepresented the observed responses by ~20%). All other models provided adequate fit upon visual inspection and scaled residuals did not exceed ±2 units at the data point closest to the predefined BMR. BMDLs for models providing adequate fit were sufficiently close (differed by less than threefold), so the model with the lowest AIC was selected (Probit). The Probit model estimated a human equivalent BMD_0.1ER_ and BMDL_10_ of 2.08 and 1.04 mg/kg-day, respectively. The results of the BMD modeling are summarized in Table C-3. Figure C-3 shows the fit of the Probit model to the data.

Table C-3 BMD Modeling Results for Hepatocyte Hypertrophy in Female Sprague Dawley Rats Orally Exposed to Dibenzothiophene for 28 Days^a^

Model | p-Value^b^ | Scaled Residual at Dose Nearest BMD | AIC | BMD_0.1ER_ (HED, (mg/kg-d) | BMDL_10_ (HED, (mg/kg-d)
Dichotomous Hill | 0.9994799 | −6.91397E−08 | 11.40673536 | 2.125982 | 1.13544
Gamma^c^ | 0.9999729 | −0.000199249 | 9.406843019 | 2.027344 | 0.974324
Log-Logistic^d^ | 0.9971634 | −4.82841E−06 | 11.40675978 | 2.104989 | 1.135448
Multistage Degree 3^e^ | 0.9957091 | −0.085479764 | 7.528643645 | 1.781135 | 0.624666
Multistage Degree 2^e^ | 0.8345974 | −0.433247713 | 8.79031287 | 1.257594 | 0.564518
Multistage Degree 1^e,f^ | 0.2663758 | −0.991744547 | 13.67071077 | 0.471974 | 0.252068
Weibull^c^ | 0.9999858 | 0.002899612 | 7.409558632 | 1.99808 | 0.881564
Logistic | 1 | 4.90622E−06 | 7.406763669 | 2.121106 | 1.125562
Log-Probit^d^ | 0.9999999 | 6.34854E−10 | 9.406734872 | 2.132271 | 1.119394
Probit ^g^ | 1 | 4.20484E−06 | 7.406737143 | 2.083075 | 1.035344

a JECDB (2011).

b Values <0.10 fail to meet conventional goodness-of-fit criteria.

c Power restricted to be ≥1.

d Slope restricted to be ≥1.

e Betas restricted to be ≥0.

f Model did not pass visual fit inspection.

g Selected model.

AIC = Akaike’s information criterion; BMD = benchmark dose; BMDL = 95% benchmark dose lower confidence limit on the BMD (subscripts denote BMR: i.e., 10 = dose associated with 10% extra risk); BMR = benchmark response; NA = test for fit is not valid; HED = human equivalent dose.

Figure C-3 Fit of Probit Model to Data for Increased Hepatocyte Hypertrophy in Female Sprague Dawley Rats Exposed to Dibenzothiophene for 28 Days (JECDB, 2011)

Figure shows the fit of probit model to data. Fit of Probit Model to Data for Increased Hepatocyte Hypertrophy in Female Sprague Dawley Rats Exposed to Dibenzothiophene for 28 Days.

BMD Model Output for Figure C-3

### Increased Relative Kidney Weight in Male Sprague Dawely Rats After Oral Treatment with Dibenzothiophene for 28 Days (JECDB, 2011)

The procedure outlined above for continuous data was applied to the data for increased relative kidney weight in male Sprague Dawley rats orally exposed to dibenzothiophene for 28 days (JECDB, 2011). The constant variance model provided an adequate fit to the variance data and only the Exponential degree 4 model provided adequate fit to the means. Visual inspection of the dose-response curve suggested adequate fit and scaled residuals did not exceed ±2 units at the data point closest to the predefined BMR. Therefore, the human equivalent BMD_0.1RD_ and BMDL_0.1RD_ values of 3.08 and 1.36 mg/kg-day, respectively, for this model were selected. The results of the BMD modeling are summarized in Table C-4. Figure C-4 shows the fit of the Exponential 4 model to the data.

Table C-4 BMD Modeling Results (Constant Variance) for Relative Kidney Weight in Male Sprague Dawley Rats Orally Exposed to Dibenzothiophene for 28 Days^a^

Model | Variance p-Value^b^ | Means p-Value^b^ | Scaled Residual at Dose Nearest BMD | AIC | BMD_0.1RD_ (HED, (mg/kg-d) | BMDL_0.1RD_ (HED, (mg/kg-d)
Exponential (model 2)^c^ | 0.24433599 | 0.0810132 | −0.493677602 | −82.13382255 | 6.069332 | 4.448717
Exponential (model 3)^c^ | 0.24433599 | 0.0810136 | −0.493536392 | −82.13383205 | 6.069183 | 4.452747
Exponential (model 4) ^c^ ^,^ ^d^ | 0.24433599 | 0.1801994 | 0.64553924 | −83.36413069 | 3.077499 | 1.364732
Exponential (model 5)^c^ | 0.24433599 | NA | 0.002299382 | −83.16003746 | 2.701189 | 0.816626
Polynomial (3-degree)^e^ | 0.24433599 | 0.0905573 | −0.519162188 | −82.35656545 | 5.918103 | 4.248669
Polynomial (2-degree)^e^ | 0.24433599 | 0.0905573 | −0.519162176 | −82.35656545 | 5.918103 | 4.248669
Power^c^ | 0.24433599 | 0.0905573 | −0.519162289 | −82.35656545 | 5.918105 | 4.249527
Linear^e^ | 0.24433599 | 0.0905573 | −0.519162316 | −82.35656545 | 5.918103 | 4.248669

a JECDB (2011).

b Values <0.10 fail to meet conventional goodness-of-fit criteria.

c Power restricted to be ≥1.

d Selected model.

e Coefficients restricted to be positive.

AIC = Akaike’s information criterion; BMD = benchmark dose; BMDL = lower confidence limit on the BMD (subscripts denote BMR: i.e., 0.1RD = dose associated with 10% relative deviation from the control); BMR = benchmark response; HED = human equivalent dose.

Figure C-4 Fit of Exponential Degree 4 Model to Data for Increased Relative Kidney Weight in Male Sprague Dawley Rats Exposed to Dibenzothiophene for 28 Days (JECDB, 2011)

BMD Model Output for Figure C-4