# APPENDIX B DATA TABLES

Table B-1 Selected Endpoints in Male and Female Sprague Dawley Rats After Oral Treatment with Dibenzothiophene for 28 Days^a^

Males: ADD [HED] in mg/kg-d^b^
Endpoint^c,d^ | 0 | 3 [0.75] | 10 [2.5] | 30 [7.4]
Motor activity (total count) | 1,399.3 ± 407.4 | 1388.3 ± 480.2 (−0.8%) | 516.7 ± 238.8^**^ (−63%) | 661.8 ± 322.1^**^ (−53%)
PT (sec) | 16.62 ± 0.87 | 17.35 ± 1.23 (+4%) | 20.48 ± 2.37^**^ (+23%) | 22.62 ± 4.19^**^ (+36%)
APTT (sec) | 28.23 ± 2.79 | 28.23 ± 3.37 (+0%) | 33.23 ± 2.16 (+18%) | 39.92 ± 6.67^**^ (+41%)
Calcium (mg/dL) | 9.55 ± 0.1 | 9.57 ± 0.28 (+0.2%) | 9.82 ± 0.38 (+3%) | 10.07 ± 0.34 (+5%)*
A/G ratio | 1.208 ± 0.123 | 1.185 ± 0.065 (−2%) | 1.175 ± 0.049 (−3%) | 1.055 ± 0.07 (−13%)^**^
Albumin protein fraction (%) | 54.65 ± 1.66 | 54.22 ± 1.35 (−0.8%) | 53.97 ± 1.07 (−1%) | 51.30 ± 1.67 (−6%)^**^
α2u-g protein fraction (%) | 7.93 ± 0.35 | 7.52 ± 0.69 (−5%) | 8.27 ± 0.2 (+4%) | 9.03 ± 0.41 (+14%)^**^
Beta globulin protein fraction (%) | 14.85 ± 0.48 | 15.02 ± 0.44 (+1%) | 15.42 ± 0.47 (+4%) | 16.95 ± 0.6 (+14%)^**^
Terminal body weight (g) | 341.8 ± 13.7 | 345.8 ± 19.3 (+1%) | 327.3 ± 28.7 (−4%) | 323.3 ± 26.1 (−5%)
Absolute liver weight (g) | 11.082 ± 1.213 | 12.170 ± 1.438 (+10%) | 11.708 ± 1.117 (+6%) | 14.468 ± 1.736^**^ (+31%)
Relative liver weight (%) | 3.233 ± 0.247 | 3.512 ± 0.271 (+9%) | 3.578 ± 0.153^*^ (+11%) | 4.465 ± 0.208^**^ (+38%)
Absolute kidney weight (g) | 2.498 ± 0.204 | 2.535 ± 0.088 (+1%) | 2.615 ± 0.355 (+5%) | 2.653 ± 0.172 (+6%)
Relative kidney weight (%) | 0.732 ± 0.040 | 0.735 ± 0.023 (+0%) | 0.798 ± 0.052^*^ (+9%) | 0.823 ± 0.031^**^ (+12%)
Terminal body weight (g) | 192.7 ± 21.4 | 211.7 ± 7.9 (+10%) | 195.7 ± 12.8 (+2%) | 195.7 ± 18.3 (+2%)
Total cholesterol (mg/dL) | 51.8 ± 14.5 | 58.3 ± 13.8 (+13%) | 51.5 ± 11.6 (+0.6%) | 79.7 ± 23.4^*^ (+54%)
Absolute liver weight (g) | 6.008 ± 0.644 | 7.100 ± 0.347^*^ (+18%) | 6.733 ± 0.555 (+12%) | 7.767 ± 0.795^**^ (+29%)
Relative liver weight (%) | 3.123 ± 0.170 | 3.355 ± 0.145 (+7%) | 3.450 ± 0.299^*^ (+10%) | 3.970 ± 0.187^**^ (+27%)
Absolute kidney weight (g) | 1.548 ± 0.141 | 1.765 ± 0.154^*^ (+14%) | 1.613 ± 0.124 (+4%) | 1.593 ± 0.154 (+3%)
Relative kidney weight (%) | 0.808 ± 0.059 | 0.837 ± 0.074 (+4%) | 0.827 ± 0.058 (+2%) | 0.818 ± 0.058 (+1%)

a JECDB (2011).

b ADDs were converted into HEDs (HED = ADD × DAF) using DAFs of 0.250, 0.248, and 0.247 for low-, mid-, and high-dose males and 0.226, 0.223, and 0.222 for low-, mid-, and high-dose females calculated as follows: DAF = (BW_a_^1/4^ ÷ BW_h_^1/4^), where BW_a_ = animal body weight, and BW_h_ = human body weight. Study-specific TWA animal body weights of 0.272, 0.264, and 0.259 kg for low-, mid-, and high-dose males, and 0.182, 0.174, and 0.171 kg for low-, mid-, and high-dose females were used. For humans, the reference value of 70 kg was used for body weight, as recommended by U.S. EPA (1988).

c Data are means ± SD; n = 6 for all data points, except n = 12 for motor activity in control and high-dose groups.

d Value in parentheses is % change relative to control = ([treatment mean − control mean] ÷ control mean) × 100.

* Significantly different from control (p < 0.05) by Dunnett’s test (motor activity, hematology, serum chemistry and organ weights) or Mann-Whitney U-test (PT time), as reported by the study authors.

** Significantly different from control (p < 0.01) by Dunnett’s test (motor activity, hematology, serum chemistry and organ weights) or Mann-Whitney U-test (PT time), as reported by the study authors.

α2u-g = alpha 2u-globulin; ADD = adjusted daily dose; A/G = albumin/globulin; APTT = activated partial thromboplastin time; DAF = dosimetric adjustment factor; HED = human equivalent dose; PT = prothrombin time; SD = standard deviation; TWA = time-weighted average.

Table B-2 Selected Histopathological Endpoints in Male and Female Sprague Dawley Rats After Oral Treatment with Dibenzothiophene for 28 Days^a^

Males: ADD [HED] in mg/kg-d^b^
Endpoint^c^ | 0 | 3 [0.75] | 10 [2.5] | 30 [7.4]
Liver (all lesions graded as slight):
Hepatocyte hypertrophy, centrilobular | 0/6 (0%) | 0/6 (0%) | 0/6 (0%) | 6/6 (100%)
Fatty change, periportal | 0/6 (0%) | 2/6 (33%) | 0/6 (0%) | 0/6 (0%)
Microgranuloma | 4/6 (67%) | 2/6 (33%) | 2/6 (33%) | 1/6 (17%)
Necrosis, focal | 0/6 (0%) | 0/6 (0%) | 0/6 (0%) | 1/6 (17%)
Kidney (proximal tubular epithelium; all lesions graded as slight):
Hyaline droplet | 0/6 (0%) | 1/6 (17%) | 2/6 (33%) | 6/6 (100%)
Eosinophilic body | 0/6 (0%) | 1/6 (17%) | 2/6 (33%) | 6/6 (100%)
Regeneration | 1/6 (17%) | 2/6 (33%) | 0/6 (0%) | 0/6 (0%)
Females: ADD [HED] in mg/kg-d
Endpoint | 0 | 3 [0.68] | 10 [2.2] | 30 [6.7]
Liver (all lesions graded as slight):
Hepatocyte hypertrophy, centrilobular | 0/6 (0%) | 0/6 (0%) | 1/6 (17%) | 6/6 (100%)
Fatty change, periportal | 3/6 (50%) | 2/6 (33%) | 0/6 (0%) | 0/6 (0%)
Microgranuloma | 4/6 (67%) | 3/6 (50%) | 3/6 (50%) | 2/6 (33%)

a JECDB (2011).

b ADDs were converted into HEDs (HED = ADD × DAF) using DAFs of 0.250, 0.248, and 0.247 for low-, mid-, and high-dose males and 0.226, 0.223, and 0.222 for low-, mid-, and high-dose females calculated as follows: DAF = (BW_a_^1/4^ ÷ BW_h_^1/4^), where BW_a_ = animal body weight, and BW_h_ = human body weight. Study-specific TWA animal body weights of 0.272, 0.264, and 0.259 kg for low-, mid-, and high-dose males, and 0.182, 0.174, and 0.171 kg for low-, mid-, and high-dose females were used. For humans, the reference value of 70 kg was used for body weight, as recommended by U.S. EPA (1988).

c Data are number of animals showing changes/ total number of animals examined (% incidence).

ADD = adjusted daily dose; DAF = dosimetric adjustment factor; HED = human equivalent dose; SD = standard deviation; TWA = time-weighted average.

Table B-3 Body, Liver, and Spleen Weights of Male Albino Rats After Dietary Exposure to Dibenzothiophene for 165 Days^a,b^

Endpoint^c^ | Percent in diet ADD [HED] in mg/kg-d^d,e,f^
Endpoint^c^ | 0^g^ | 0.025% | 0^h^ | 0.050% | 0^i^ | 0.100%
Endpoint^c^ | 0 | 13 [2.9] | 0 | 27 [5.9] | 0 | 63 [13]
Terminal body weight (g) | 310 | 310 | 273 | 273 | 212 | 212
Absolute liver weight (g) | 10.00 ± 0.11 | 10.70 ± 0.29 (+7%) | 9.50 ± 0.27 | 12.80 ± 0.48 (+35%) | 8.40 ± 0.22 | 18.10 ± 0.74 (+115%)
Absolute spleen weight (g) | 0.97 ± 0.062 | 0.69 ± 0.015 (−29%) | 0.92 ± 0.072 | 0.64 ± 0.067 (−30%) | 0.83 ± 0.041 | 0.36 ± 0.010 (−57%)
Absolute spleen weight (g) | 0.97 ± 0.062 | 0.69 ± 0.015 (−29%) | 0.92 ± 0.072 | 0.64 ± 0.067 (−30%) | 0.83 ± 0.041 | 0.36 ± 0.010 (−57%)

a Thomas et al. (1942).

b Statistical analysis was not reported and is not conducted because number of animals per group was not reported.

c Organ weights are expressed as mean ± probable error; value in parentheses is % change relative to matched laboratory historical control = ([treatment mean − control mean] ÷ control mean) × 100.

d Animals were provided dibenzothiophene in the food at 0.25, 0.50, or 1.00% for the first 4 days. Because of low food intakes and decreases in body weight, doses were then decreased to 0.025, 0.050, or 0.100% dibenzothiophene for the remainder of the 165-day study period. The study authors provided the amount of dibenzothiophene consumed. The following equation was used to convert that information to mg/kg-day: ADD = total dibenzothiophene consumption per animal over study duration × (1 ÷ body weight) × (1 ÷ days dosed)

e ADDs were converted to HEDs by multiplying by DAFs of 0.225, 0.219, and 0.208 for low-, mid-, and high-dose rats calculated as follows: DAF = (BW_a_^1/4^ ÷ BW_h_^1/4^), where BW_a_ = animal body weight, and BW_h_ = human body weight. Study-specific estimated average animal body weights of 0.179, 0.161, and 0.130 kg for low-, mid-, and high-dose rats were used. For humans, the reference value of 70 kg was used for body weight, as recommended by U.S. EPA (1988).

f Data for each exposure group were compared with data for laboratory historical controls. For the evaluation of organ weights, historical controls were matched according to body weight.

g Matched laboratory historical controls for 13-mg/kg-day dose group.

h Matched laboratory historical controls for 27-mg/kg-day dose group.

i Matched laboratory historical controls for 63-mg/kg-day dose group.

ADD = adjusted daily dose; DAF = dosimetric adjustment factor; HED = human equivalent dose; TWA = time-weighted average.