# APPENDIX A SCREENING PROVISIONAL VALUES

Due to the lack of evidence described in the main Provisional Peer-Reviewed Toxicity Value (PPRTV) document, it is inappropriate to derive provisional toxicity values for dibenzothiophene. However, some information is available for this chemical, which although insufficient to support derivation of a provisional toxicity value under current guidelines, may be of limited use to risk assessors. In such cases, the Center for Public Health and Environmental Assessment (CPHEA) summarizes available information in an appendix and develops a “screening value.” Appendices receive the same level of internal and external scientific peer review as the provisional reference values to ensure their appropriateness within the limitations detailed in the document. Users of screening toxicity values in an appendix to a PPRTV assessment should understand that there could be more uncertainty associated with deriving an appendix screening toxicity value than for a value presented in the body of the assessment. Questions or concerns about the appropriate use of screening values should be directed to the CPHEA.

A screening subchronic provisional reference doses (p-RfD) was derived for dibenzothiophene as described in the section below. For inhalation, an alternative analogue approach was evaluated (see APPLICATION OF AN ALTERNATIVE ANALOGUE APPROACH (METHODS) below), but suitable analogues were not identified and a screening value was not derived.

## DERIVATION OF SCREENING PROVISIONAL REFERENCE DOSES

As discussed in the main body of the report, the available repeat-dose oral studies for dibenzothiophene include only JECDB (2011) and Thomas et al. (1942), both of which have limitations precluding their use in deriving provisional toxicity values. In order to account for the uncertainty associated with basing a toxicity assessment on these studies, the assessment is considered a screening-level assessment.

The 28-day oral exposure study by JECDB (2011) is limited by unpublished status, lack of peer review, and use of Japanese language with only tables and figures in English. There was enough material presented in English, however, to ascertain that the study appeared to be adequately designed and conducted, and to provide dose-response information on a wide range of endpoints suitable for use in quantitative toxicity assessment, including body weight, food consumption, clinical observations, functional observational battery (FOB), hematology, serum chemistry, urinalysis, and selected organ weight and histopathology (see study summary in Section 2.2.1 for more details). Liver effects were a sensitive target for dibenzothiophene in the JECDB (2011) study. Dose-related and biologically significant (≥10%) increases in relative liver weight were reported in both male and female rats at ≥10 mg/kg-day and were a primary basis for the study reported no-observed-adverse-effect level (NOAEL)/lowest-observed-adverse-effect level (LOAEL) values (NOAEL = 3 mg/kg-day and LOAEL = 10 mg/kg-day). The relative liver weight changes were accompanied by increased incidence of hepatocyte hypertrophy in both sexes at ≥10 mg/kg-day (1/6 females at 10 mg/kg-day and 6/6 males and females at 30 mg/kg-day) and possible evidence of structural degeneration (slight necrosis in 1/6 animals) and changes in serum markers of liver damage (decreased albumin protein fraction and albumin/globulin [A/G] ratio]) in males at 30 mg/kg-day. Although increases (≥10%) in absolute liver weights were observed in rats at ≥3 mg/kg-day, the changes at the lowest dose were not supported by corroborative evidence of liver toxicity and overall pattern of effects lacked a dose-response relationship (see Table B-1). The findings across organ weight, histopathology, and clinical chemistry measures provide coherent evidence of liver toxicity after short-term oral exposure to dibenzothiophene.

Other treatment-related effects observed at the JECDB (2011) study LOAEL of 10 mg/kg-day included significant reductions in motor activity, although there was no corroborative evidence from other FOB assays evaluating reactivity (visual, touch, auditory, pain, proprioceptive), righting reflex, or grip strength. Additionally, significant increases in prothrombin time (PT) were reported in males at ≥10 mg/kg-day, accompanied by significant increases in activated partial thromboplastin time (APTT) at 30 mg/kg-day in these animals. Prolonged clotting times (i.e., increased PT and APTT) are consistent with findings of dibenzothiophene-induced platelet aggregation in vitro (Chaudhury et al., 1988), and decreased motor activity is consistent with findings of decreased viability of differentiated SK-N-SH human neuroblastoma cells with in vitro dibenzothiophene exposure (Sarma et al., 2017). However, there is limited in vivo evidence to determine the biological significance of the changes in motor activity and prolonged clotting times in males.

Male rats in the JECDB (2011) study exhibited biologically significant increases (≥10%) in relative kidney weights at 30 mg/kg-day. Dose-related increases in the incidence of hyaline droplets and eosinophilic bodies in the proximal tubular epithelium of the kidney (one of six, two of six, and six of six animals at 3, 10, and 30 mg/kg-day, respectively) also occurred in males. Accumulation of hyaline droplets (also described as cytoplasmic eosinophilic bodies containing protein) are commonly associated with alpha 2u-globulin (α2u-g)-mediated nephropathy (Hard et al., 1999), a male rat-specific nephropathy not considered relevant to humans. According to (U.S. EPA, 1991), three criteria are required for evaluating the relevance of kidney lesions in males based on possible involvement of α2u-g: (1) observation of an increase in number and size of hyaline droplets only in male kidneys; (2) identification of the protein contained in the hyaline droplets as α2u-g; and (3) observation of additional events in the pathological sequence of lesions associated with α2u-g disease (i.e., single cell necrosis, exfoliation of epithelial cells into tubular lumen, and granular casts). The evidence for dibenzothiophene is limited to increases in hyaline droplets occurring only in male rats in the 28-day JECDB (2011) study. Given that the study is in Japanese, it is unclear whether the study authors performed any specialized staining for detection of α2u-g and no additional observations were made regarding other events in the pathological sequence of the development of α2u-g disease. Further, there is no supporting evidence for α2u-g-, including the 165-day study by Thomas et al. (1942). Thomas et al. (1942) reported slight-to-moderate, light brown, granular pigmentation in the epithelial cells of the proximal convoluted tubules of male rats (with no evidence of cell destruction) but no other details were provided; therefore, the toxicological significance of the findings is unknown. The limitations in the database for dibenzothiophene prevent further interpretation of the relevance of the male rat kidney lesions in the JECDB (2011) study. Given the uncertainty and lack of information for further evaluation, these kidney lesions in male rats (hyaline droplets and eosinophilc bodies) were not further considered for dose-response analysis.

The 165-day dietary exposure study in rats by Thomas et al. (1942) had outstanding limitations such as the lack of a concurrent control group, instead making inferences based on historical control groups. Other limitations included the use of males only, lack of reporting on the number of test animals per group, and incomplete data reporting for histopathological outcomes. The major study findings were increases in liver weight that reached 35% at 27 mg/kg-day and 115% at 63 mg/kg-day (over body-weight-matched laboratory historical controls). Histopathological lesions in the liver (i.e., fat accumulation, irregular vacuolation of the parenchymal cells [hepatocytes] throughout the lobules, and indications that adjacent cells had fused) were also observed at all doses; however, incidence of lesions was not provided, and severity was described as much less in the low- and mid-dose groups (13 and 27 mg/kg-day) compared to the high-dose group (63 mg/kg-day). Although the study limitations add considerable uncertainty to the interpretation of the findings or the determination of NOAEL/LOAEL values, these observations are consistent with the liver effects in the JECDB (2011) study, providing supportive evidence of dibenzothiophene-induced liver toxicity.

Overall, the increases in relative liver weight and liver lesions (primarily hypertrophy) and decreases in serum markers of liver function (albumin protein fraction and A/G ratio) provide coherent evidence of liver effects in rats at ≥10 mg/kg-day after 28-day exposure (JECDB, 2011). Although the relevance of male kidney lesions reported in the JECDB (2011) study is unclear, the changes in relative kidney weights in males at 30 mg/kg-day were considered biologically significant (≥10%). Therefore, both the liver effects and relative kidney weight changes from this study were considered further for the derivation of screening p-RfDs. Other treatment-related effects (decreased motor activity, increased PT and APTT and increased hyaline droplets in males) in the JECDB (2011) study were not advanced for dose-response analysis due to the limitations in the database for dibenzothiophene, which prevent further determination of the toxicological significance of the findings.

### Derivation of Screening Subchronic Provisional Reference Dose

Data for liver effects in male and female rats and increased relative kidney weights in male rats from the JECDB (2011) study were modeled using the U.S. Environmental Protection Agency (U.S. EPA) Benchmark Dose Software (BMDS, Version 3.2). Despite the non-peer-reviewed status and lack of full English language report, the study used an adequate design (28-day rat study), included multiple doses and a comprehensive array of toxicity endpoints, and identified sensitive health effects that are suitable for the derivation of the screening subchronic p-RfD (JECDB, 2011). For liver effects, dose-related increases in relative liver weight in males and females at ≥10 mg/kg-day were modeled as continuous data using a benchmark response (BMR) of 10% relative deviation (RD) because a 10% change in liver weight is considered a minimally biologically significant response in adult animals. Hepatocyte hypertrophy was modeled in females as dichotomous data, applying a standard BMR of 10% extra risk (ER). Hepatocyte hypertrophy in males was not modeled given that the effects were only observed in the high-dose group. Although the decreases in some serum markers of liver function (albumin protein fraction and A/G ratio) in male rats provide supporting evidence for dibenzothiophene-induced liver effects, these endpoints were not considered for dose-response assessment since more sensitive and relevant markers of liver toxicity were available (i.e., relative liver weight and hepatocyte hypertrophy). Increased relative kidney weight in males were modeled as continuous data using a BMR of 10%, which is considered biologically significant. Human equivalent doses (HEDs) in mg/kg-day were used as the dose metric for BMD analysis.

Table A-1 shows the data for liver and kidney endpoints that were considered for dose-response assessment and Table A-2 summarizes the BMD modeling results and provides candidate points of departure (PODs) for the derivation of the screening subchronic p-RfD. Details of model fit for each data set are presented in Appendix C. Candidate PODs that could not be evaluated via BMD analysis (i.e., hepatocyte hypertrophy in males) are presented as NOAEL/LOAEL values.

Table A-1 Data for Sensitive Endpoints in Male and Female Sprague Dawley Rats After Oral Treatment with Dibenzothiophene for 28 Days^a^

Endpoint | ADD [HED] in mg/kg-d^b^
| 0 | 3 [0.68 female, 0.75 male] | 10 [2.2 female, 2.5 male] | 30 [6.7 female, 7.4 male]
Increased relative liver weight in males^c^ | 3.233 ± 0.247 | 3.512 ± 0.271 (+9%) | 3.578 ± 0.153^*^ (+11%) | 4.465 ± 0.208^**^ (+38%)
Increased relative liver weight in females^c^ | 3.123 ± 0.170 | 3.355 ± 0.145 (+7%) | 3.450 ± 0.299^*^ (+10%) | 3.970 ± 0.187^**^ (+27%)
Increased hepatocyte hypertrophy in males^d^ | 0/6 (0%) | 0/6 (0%) | 0/6 (0%) | 6/6 (100%)
Increased hepatocyte hypertrophy in females^d^ | 0/6 (0%) | 0/6 (0%) | 1/6 (17%) | 6/6 (100%)
Increased relative kidney weight in males^c^ | 0.732 ± 0.040 | 0.735 ± 0.023 (+0%) | 0.798 ± 0.052^*^ (+9%) | 0.823 ± 0.031^**^ (+12%)

a JECDB (2011).

b ADDs were converted into HEDs (HED = ADD × DAF) using DAFs of 0.250, 0.248, and 0.247 for low-, mid-, and high-dose males and 0.226, 0.223, and 0.222 for low-, mid-, and high-dose females calculated as follows: DAF = (BW_a_^1/4^ ÷ BW_h_^1/4^), where BW_a_ = animal body weight, and BW_h_ = human body weight. Study-specific TWA animal body weights of 0.272, 0.264, and 0.259 kg for low-, mid-, and high-dose males, and 0.182, 0.174, and 0.171 kg for low-, mid-, and high-dose females were used. For humans, the reference value of 70 kg was used for body weight, as recommended by U.S. EPA (1988).

c Data are means ± SD; n = 6 for all data points; value in parentheses is % change relative to control = ([treatment mean − control mean] ÷ control mean) × 100.

d Data are number of animals showing changes/ total number of animals examined (% incidence).

* Significantly different from control (p < 0.05) by Dunnett’s test as reported by the study authors.

** Significantly different from control (p < 0.01) by Dunnett’s test as reported by the study authors.

ADD = adjusted daily dose; DAF = dosimetric adjustment factor; HED = human equivalent dose; SD = standard deviation; TWA = time-weighted average.

Table A-2 Comparison of Candidate POD Values in Male and Female Sprague Dawley Rats After Oral Treatment with Dibenzothiophene for 28 Days^a^

Endpoint | Best-Fitting Model | BMR | BMDL (HED) (mg/kg-d) | POD type | POD (HED) (mg/kg-d)
Increased relative liver weight in males | Exponential 3 (constant variance) | 10% RD from control (0.1 RD) | 2.01 | BMDL | 2.01
Increased relative liver weight in females | Linear (constant variance) | 10% RD from control (0.1 RD) | 2.19 | BMDL | 2.19
Increased hepatocyte hypertrophy in males | Data not amenable for BMD modeling^b^ | | | NOAEL | 2.5
Increased hepatocyte hypertrophy in females | Probit (constant variance) | 10% ER from control (0.1 ER) | 1.04 | BMDL | 1.04
Increased relative kidney weight in males | Exponential 4 (constant variance) | 10% RD from control (0.1 RD) | 1.36 | BMDL | 1.36

a JECDB (2011).

b Data were not considered amenable for BMD modeling given that incidence was 100% at the highest dose and 0% at lower doses.

BMD = benchmark dose; BMDL = benchmark dose lower confidence limit; BMR = benchmark response; ER = Extra Risk; HED = human equivalent dose; NOAEL = no-observed-adverse-effect level; POD = point of departure; RD = relative deviation.

The 10% benchmark dose lower confidence limit (BMDL_10_) (HED) of 1.04 mg/kg-day for increased hepatocyte hypertrophy in female rats in the JECDB (2011) study is the lowest POD in the available database and is expected to be protective of other health effects associated with dibenzothiophene oral exposure. The significance of dibenzothiophene-induced liver effects is based on coherent evidence across organ weights (increased relative liver weight), histopathology (primarily hypertrophy with some evidence of necrosis), and serum markers of liver function (decreased albumin protein fraction and A/G ratio) in rats at ≥10 mg/kg-day after 28-day oral exposure (JECDB, 2011). Supportive evidence of potential liver toxicity was also found after dietary exposure for 165 days in males rats (increased liver weight and fatty accumulation in the liver at ≥27 mg/kg-day) (Thomas et al., 1942) and acute gavage range-finding and median lethal dose (LD_50_) experiments in mice (centrilobular degeneration and necrosis across 260−1,609 mg/kg) (Leighton, 1989). Altogether, the weight of evidence suggests that the liver is a primary target for dibenzothiophene via oral exposure and the BMDL_10_ [HED] of 1.04 mg/kg-day for increased hepatocyte hypertrophy in female rats exposed for 28 days (JECDB, 2011) is selected as the most sensitive POD for the derivation of the subchronic p-RfD.

The screening subchronic p-RfD of 3 × 10^−3^ mg/kg-day for dibenzothiophene is derived by applying a composite uncertainty factor (UF_C_) of 300 (reflecting an interspecies uncertainty factor [UF_A_] of 3, an interindividual variability uncertainty factor [UF_H_] of 10, and a database uncertainty factor [UF_D_] of 10) to the selected POD of 1.04 mg/kg-day, as follows:

Screening Subchronic p-RfD = POD ( HED ) ÷ UF_C_ = 1.04 mg / kg-day ÷ 300 = 3 × 10^− 3^ mg / kg-day

Table A-3 summarizes the uncertainty factors for the screening subchronic p-RfD for dibenzothiophene.

Table A-3 Uncertainty Factors for the Screening Subchronic p-RfD for Dibenzothiophene (CASRN 132-65-0)

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^) is applied to account for uncertainty in characterizing the toxicodynamic differences between rats and humans following oral dibenzothiophene exposure. The toxicokinetic uncertainty has been accounted for by calculation of an HED through application of a DAF as outlined in the U.S. EPA’s Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011c).
UF_D_ | 10 | A UF_D_ of 10 is applied to account for deficiencies and uncertainties in the database. The repeat-dose oral database for dibenzothiophene includes a non-peer-reviewed, 28-day rat study in Japanese and a chronic rat study with significant limitations (primarily lack of a concurrent control and reporting on the number of test animals). No reproductive or developmental toxicity studies are available by any route of exposure.
UF_H_ | 10 | A UF_H_ of 10 is applied for interindividual variability to account for human-to-human variability in susceptibility in the absence of quantitative information to assess the toxicokinetics and toxicodynamics of dibenzothiophene in humans.
UF_L_ | 1 | A UF_L_ of 1 is applied because the POD is a BMDL.
UF_S_ | 1 | A UF_S_ of 1 is applied because the POD was derived from a study of suitable duration (28 days) for a subchronic value.
UF_C_ | 300 | Composite UF = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_.

DAF = dosimetric adjustment factor; HED = human equivalent dose; POD = point of departure; BMDL = benchmark dose lower confidence limit; p-RfD = provisional reference dose; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

### Derivation of Screening Chronic Provisional Reference Dose

The POD used for derivation of the screening subchronic p-RfD based on increased hepatocyte hypertrophy in female rats (BMDL_10_ [HED] of 1.04 mg/kg-day) from the 28-day study by JECDB (2011), cannot be used directly for derivation of the screening chronic p-RfD, due to the short duration of the critical study. The available 165-day chronic study by Thomas et al. (1942) reported increases in liver weight and liver histopathology at ≥27 mg/kg-day, which are similar to the doses associated with liver effects in the 28-day JECDB (2011) study (≥10 mg/kg-day). However, the limitations in the study design and data reporting in Thomas et al. (1942) raise significant concerns regarding the interpretation of the study findings. Overall, the lack of adequate data to inform whether the liver or other health effects associated with dibenzothiophene worsen with chronic exposure prevent the derivation of a screening chronic p-RfD.

## APPLICATION OF AN ALTERNATIVE ANALOGUE APPROACH (METHODS)

The analogue approach allows for the use of data from related compounds to calculate screening values when data for the compound of interest are limited or unavailable. Details regarding searches and methods for analogue analysis are presented in Wang et al. (2012). Three types of potential analogues (structural, metabolic, and toxicity-like) are identified to facilitate the final analogue chemical selection. The analogue approach may or may not be route-specific or applicable to multiple routes of exposure. All information was considered together as part of the final weight-of-evidence (WOE) approach to select the most suitable analogue both toxicologically and chemically.

An expanded analogue identification approach was developed to collect a more comprehensive set of candidate analogues for the compounds undergoing a U.S. EPA PPRTV screening-level assessment. As described below, this method includes application of a variety of tools and methods for identifying candidate analogues that are similar to the target chemical based on chemical structure and key features; metabolic relationships; or related toxic effects and mechanisms of action.

To identify structurally-related compounds, an initial pool of analogues is identified using automated tools, including ChemIDplus (ChemIDplus, 2021), CompTox Chemicals Dashboard (U.S. EPA, 2021b), and Organisation for Economic Co-operation and Development (OECD) Quantitative Structure-Activity Relationship (QSAR) Toolbox (OECD, 2021), to conduct structural similarity searches. Additional analogues identified as ChemIDplus-related substances, parent, salts, and mixtures, and CompTox-related substances are considered. CompTox GenRA analogues are collected using the methods available on the publicly available GenRA Beta version, which may include Morgan fingerprints, Torsion fingerprints, ToxPrints and ToxCast, Tox21, and ToxRef data. For compounds that have very few analogues identified by structure similarity using a similarity threshold of 0.8 or 80%, substructure searches in the QSAR Toolbox may be performed, or similarity searches may be rerun using a reduced similarity threshold (e.g., 70 or 60%). The compiled list of candidate analogues is batch run through the CompTox Chemicals Dashboard where QSAR-ready simplified molecular-input line-entry system (SMILES) are collected and toxicity data availability is determined (e.g., from the Agency for Toxic Substances and Disease Registry [ATSDR], Office of Environmental Health Hazard Assessment [OEHHA), California Environmental Protection Agency [CalEPA], U.S. EPA Integrated Risk Information System [IRIS], PPRTVs). The batch output information is then uploaded into the Chemical Assessment Clustering Engine (ChemACE) (U.S. EPA, 2011a), which clusters the chemicals based on chemical fragments and displays the toxicity data availability for each candidate. The ChemACE output is reviewed by an experienced chemist, who narrows the list of structural analogues based on known or expected structure-toxicity relationships, reactivity, and known or expected metabolic pathways.

Toxicokinetic studies identified from the literature searches performed for this PPRTV assessment were used to identify metabolic analogues (metabolites and metabolic precursors). Metabolites were also identified from the two OECD QSAR Toolbox metabolism simulators (in vivo rat metabolism simulator and rat liver S9 metabolism simulator). Targeted PubMed searches were conducted to identify metabolic precursors and other compounds that share any of the observed or predicted metabolites identified for the target chemical. Metabolic analogues are then added to the pool of candidate analogues and toxicity data availability is determined (e.g., from ATSDR, OEHHA, CalEPA, U.S. EPA IRIS, PPRTVs).

In vivo toxicity data for the target chemical (if available from the literature searches) are evaluated to determine whether specific or characteristic toxicity was observed (e.g., cholinesterase inhibition, inhibition of oxidative phosphorylation). In addition, in vitro mechanistic data identified from the literature searches or obtained from tools including GenRA, ToxCast/Tox21, and Comparative Toxicogenomics Database (CTD) (Davis et al., 2021) were evaluated for this purpose. Data from CompTox Chemicals Dashboard ToxCast/Tox21 are collected to determine bioactivity of the target chemical in in vitro assays that may indicate potential mechanism(s) of action. The GenRA option within the Dashboard also offers an option to search for analogues based on similarities in activity in ToxCast/Tox21 in vitro assays. Using the ToxCast/Tox21 bioactivity data, nearest neighbors identified with similarity indices of ≥0.5 may be considered potential candidate analogues. The CTD (Davis et al., 2021) is searched to identify compounds with gene interactions similar to interactions induced by the target chemical; compounds with gene interactions similar to the target chemical (with a similarity index >0.5) may be considered potential candidate analogues. These compounds are then added to the pool of candidate analogues, and toxicity data availability is determined (e.g., from ATSDR, OEHHA, CalEPA, U.S. EPA IRIS, PPRTVs).

The tools used for the expanded analogue searches were selected because they are publicly available, which allows for transparency and reproducibility of the results, and because they are supported by U.S. and OECD agencies, updated regularly, and widely used. The application of a variety of different tools and methods to identify candidate analogues serves to minimize the limitations of any individual tool with respect to the pool of chemicals included, chemical fragments considered, and methods for assessing similarity. Further, the inclusion of techniques to identify analogues based on metabolism and toxicity or bioactivity expands the pool of candidates beyond those based exclusively on structural similarity.

### Analogue Search Results for Dibenzothiophene

Candidate analogues for dibenzothiophene were identified based on structural relationships, metabolic relationships, and toxicity/mechanisms/mode-of-action (MOA) relationships. For candidates identified through these approaches, U.S. EPA (IRIS and PPRTV), ATSDR, and CalEPA sources were searched for subchronic, intermediate, and chronic inhalation toxicity values. No candidate analogues with inhalation toxicity values were identified. Details are provided below.

#### Identification of Structural Analogues with Established Toxicity Values

Dibenzothiophene is not a member of an existing OECD or New Chemical category. Candidate structural analogues for dibenzothiophene were identified using similarity searches in the OECD Toolbox, U.S. EPA CompTox Chemicals Dashboard, and ChemIDplus tools. A total of 24 unique structural analogues were identified for dibenzothiophene in the Dashboard, OECD QSAR Toolbox, and ChemIDplus (≥80% similarity threshold) (NLM, 2021a; OECD, 2020).

The list of potential analogues was manually reviewed and the following criteria were applied to select candidate analogues for further evaluation based on the structural features expected to influence toxicokinetics and/or toxicity,:

- Contains one thiophene ring fused with 1–3 benzene rings, and
- Only methyl, ethyl, or propyl alkyl substituents are present.

Using these criteria, all 24 structural analogues initially identified were considered candidate analogues for dibenzothiophene (see Table A-4). No inhalation toxicity values were identified for any of the candidate structural analogues.

Table A-4 Candidate Structural Analogues Identified for Dibenzothiophene

Dibenzothiophene structural diagram

Tool (Method)^a^ | Analogue (CASRNs) Selected for Toxicity Value Searches | Structure
Dashboard (Tanimoto), OECD Toolbox, and ChemIDplus (method not described) | Benzo[b]naphtho[2,1-d]thiophene (239-35-0) | Structural Analogues selected for toxicity values searches: Benzo[b]naphtho[2,1-d]thiophene (239-35-0)
Dashboard (Tanimoto), OECD Toolbox, and ChemIDplus (method not described) | Benzo[b]naphtho[2,3-d]thiophene (243–46-9) | Structural Analogues selected for toxicity values searches: Benzo[b]naphtho[2,3-d]thiophene (243-46-9)
Dashboard (Tanimoto) ChemIDplus (method not described) | 2,8-Dimethyldibenzo[b,d]thiophene (1207–15-4) | Structural Analogues selected for toxicity values searches for 2,8-Dimethyldibenzo[b,d]thiophene (1207-15-4) 2D chemical structure of 1207-15-4
Dashboard (Tanimoto) ChemIDplus (method not described) | 2-Methyldibenzothiophene (30995–64-3) | Structural Analogues selected for toxicity values searches for 2-Methyldibenzothiophene (CASRN 30995-64-3)
OECD Toolbox, and ChemIDplus (method not described) | 3-Methyldibenzothiophene (16587–52-3) | Structural Analogues selected for toxicity values searches for 3-Methyldibenzothiophene (CASRN 16587-52-3)
Dashboard (Tanimoto) | Naphtho(2,1-b)thiophene (233–02-3) | Structural Analogues selected for toxicity values searches for Naphtho(2,1-b)thiophene (CASRN 233-02-3)
Dashboard (Tanimoto) | Naphtho(1,2-b)thiophene (234–41-3) | Structural Analogues selected for toxicity values searches: Naphtho(1,2-b)thiophene (CASRN 234-41-3)
Dashboard (Tanimoto) | Naphtho(2,3-b)thiophene (268–77-9) | Structural Analogues selected for toxicity values searches: Naphtho(2,3-b)thiophene (CASRN 268-77-9)
Dashboard (Tanimoto) | Anthra(2,3-b)thiophene (22108–55-0) | Structural Analogues selected for toxicity values searches: Anthra(2,3-b)thiophene (CASRNs 22108-55-0)
Dashboard (Tanimoto) | Anthra(2,1-b)thiophene (227–56-5) | Structural Analogues selected for toxicity values searches: Anthra(2,1-b)thiophene (CASRN 227-56-5)
Dashboard (Tanimoto) | Anthra(1,2-b)thiophene (227–86-1) | Structural Analogues selected for toxicity values searches: Anthra(1,2-b)thiophene (CASRN 227-86-1)
Dashboard (Tanimoto) | Benzo(b)naphtho(2,3-d)thiophene, 8-methyl- (24964–07-6) | Structural Analogues selected for toxicity values searches: Benzo(b)naphtho(2,3-d)thiophene, 8-methyl- (CASRN 16587-52-3)
Dashboard (Tanimoto) | Benzo(b)naphtho(2,3-d)thiophene, 9-methyl- (41895–72-1) | Structural Analogues selected for toxicity values searches: Benzo(b)naphtho(2,3-d)thiophene, 9-methyl- (CASRN 41895-72-1)
Dashboard (Tanimoto) | Benzo(b)naphtho(2,1-d)thiophene, 2-methyl- (4567–43-5) | Structural Analogues selected for toxicity values searches: Benzo(b)naphtho(2,1-d)thiophene, 2-methyl- (CASRN 4567-43-5)
Dashboard (Tanimoto) | Benzo(b)naphtho(2,1-d)thiophene, 3-methyl- (4567–45-7) | Structural Analogues selected for toxicity values searches: Benzo(b)naphtho(2,1-d)thiophene, 3-methyl- (CASRN 4567-45-7)
Dashboard (Tanimoto) | Benzo(b)naphtho(2,3-d)thiophene, 2-methyl- (83656–84-2) | Structural Analogues selected for toxicity values searches: Benzo(b)naphtho(2,3-d)thiophene, 2-methyl- (CASRN 83656-84-2)
Dashboard (Tanimoto) | Benzo(b)naphtho(2,1-d)thiophene, 8-methyl- (83821–53-8) | Structural Analogues selected for toxicity values searches: Benzo(b)naphtho(2,1-d)thiophene, 8-methyl- (CASRN 83821-53-8)
ChemIDplus (method not described) | Dibenzothiophene, 2-methyl- (20928–02-3) | Structural Analogues selected for toxicity values searches: Dibenzothiophene, 2-methyl- (CASRN 20928-02-3)
ChemIDplus (method not described) | Dibenzothiophene, 1-methyl- (31317–07-4) | Structural Analogues selected for toxicity values searches: Dibenzothiophene, 1-methyl- (CASRN 31317-07-4)
ChemIDplus (method not described) | Dimethyldibenzothiophene (70021–47-5) | Structural Analogues selected for toxicity values searches: Dimethyldibenzothiophene (CASRN 70021-47-5)
ChemIDplus (method not described) | Dibenzothiophene, 4-methyl- (7372–88-5) | Structural Analogues selected for toxicity values searches: Dibenzothiophene, 4-methyl- (CASRN 7372-88-5)
ChemIDplus (method not described) | 1-Ethyldibenzo[b,d]thiophene (79313–22-7) | Structural Analogues selected for toxicity values searches: 1-Ethyldibenzo[b,d]thiophene (CASRN 79313-22-7)
ChemIDplus (method not described) | 4-Ethyldibenzothiophene (89816–99-9) | Structural Analogues selected for toxicity values searches: 4-Ethyldibenzothiophene (CASRN 89816-99-9)
ChemIDplus (method not described) | 1-Propyldibenzo[b,d]thiophene (79313–23-8) | Structural Analogues selected for toxicity values searches: 1-Propyldibenzo[b,d]thiophene (CASRN 79313-23-8)

a 80% similarity threshold was applied.

OECD = Organisation for Economic Co-operation and Development.

#### Identification of Toxicokinetic Precursors or Metabolites with Established Toxicity Values

The main metabolite in urine from a rabbit exposed orally to dibenzothiophene was mono-hydroxy-diphenylene sulfone (Thomas et al., 1942). In rat liver microsomes incubated with dibenzothiophene, the identified metabolites were dibenzothiophene-5-oxide and dibenzothiophene-5-dioxide (dibenzothiophene sulfone) (Jacob et al., 1991; Vignier et al., 1985). Predicted metabolites were collected from the OECD QSAR Toolbox. PubMed searches (searching “dibenzothiophene” or “132–65-0” and “metabolite”) were conducted to identify metabolic precursors to dibenzothiophene. No metabolic precursors were identified. PubMed was also searched to identify other compounds that are metabolized to any of the observed or predicted metabolites of dibenzothiophene (searching the metabolite name or [CASRN if available] and “metabolite”). No compounds that share at least one metabolite with dibenzothiophene were identified in these searches.

Table A-5 summarizes the 18 candidate metabolic analogues for dibenzothiophene (3 observed metabolites and an additional 15 unique predicted metabolites). Searches for relevant toxicity values for the candidate metabolic analogues of dibenzothiophene did not identify inhalation toxicity values for any of the observed/predicted metabolites.

Table A-5 Candidate Metabolic Analogues of Dibenzothiophene

Relationship to Dibenzothiophene | Compound
Metabolic precursor | None identified
Metabolite | Mono-hydroxy-dibenzothiophene sulfone (location of hydroxy group not specified)
Metabolite | Dibenzothiophene 5-oxide (CASRN 1013-23-6)
Metabolite | Dibenzothiophene sulfone (CASRN 1016-05-3)
Metabolite | 2-Hydroxydibenzothiophene (CASRN 22439-65-2)
Metabolite | 3-Hydroxydibenzothiophene (CASRN 69747-77-9)
Metabolite | 4-Hydroxydibenzothiophene (CASRN 24444-75-5)
Metabolite | 2,3-Dihydroxydibenzothiophene^a^
Metabolite | 3,4-Dihyroxydibenzothiophene^a^
Metabolite | 3,7-Dihydroxydibenzothiophene^a^
Metabolite | 3,4,7-Trihydroxydibenzothiophene^a^
Metabolite | 2,3,7-Trihydroxydibenzothiophene^a^
Metabolite | 2-Hydroxydibenzothiophene 5-oxide^a^
Metabolite | 3-Hydroxydibenzothiophene 5-oxide^a^
Metabolite | 4-Hydroxydibenzothiophene 5-oxide^a^
Metabolite | 2,3-Hydroxydibenzothiophene 5-oxide^a^
Metabolite | 3,4-Hydroxydibenzothiophene 5-oxide^a^
Metabolite | 3,7-Hydroxydibenzothiophene 5-oxide^a^
Metabolite | 1-Hydroxydibenzothiophene (CASRN 69747-83-7)
Shares common metabolite(s) | None identified

a CASRN not available for this metabolite.

#### Identification of Analogues on the Basis of Toxicity/Mechanistic/Mode-of-Action Information and Established Toxicity Values

Available toxicity and mechanistic data for dibenzothiophene were evaluated to determine whether these data would suggest candidate analogues. The data were reviewed to determine whether there were in vivo toxicity data suggesting specific, characteristic toxicity (e.g., cholinesterase inhibition, inhibition of oxidative phosphorylation) that could be used to identify candidate analogues. The limited available in vivo animal data on dibenzothiophene administered orally indicate that the liver is the primary target organ and increased hepatocyte hypertrophy in female rats exposed for 28 days. JECDB (2011) was used as a critical effect for the derivation of the screening subchronic p-RfD value (see “DERIVATION OF SCREENING PROVISIONAL REFERENCE DOSES” section for more details). However, the available information was not sufficient to suggest specific, characteristic toxicity that could be used to identify candidate analogues.

Dibenzothiophene was active in 25 ToxCast/Tox21, 6 EDSP21, and 83 PubChem bioactivity assays reported in the U.S. EPA CompTox Chemicals Dashboard. The GenRA option within the Dashboard offers an option to search for analogues based on similarities in activity in ToxCast in vitro assays. Using the ToxCast bioactivity data, none of the nearest neighbors identified by GenRA had similarity indices ≥0.5 (the highest index was 0.28 for pentachloroanisole).

The CTD identified several compounds with gene interactions similar to interactions induced by dibenzothiophene (Davis et al., 2021). In the CTD, similarity is measured by the Jaccard index, calculated as the size of the intersection of interacting genes for chemical A and chemical B divided by the size of the union of those genes (range 0 [no similarity] to 1 [complete similarity]). Among the compounds with gene interactions similar to dibenzothiophene, the numbers of common gene interactions ranged from 23 to 145, and similarity indices ranged from 0.03 to 0.16; the compound with the highest similarity index (0.16) was pyrene. There were no compounds with a similarity index over 0.5.

#### Summary

Searches for structural, metabolic, and toxicity/mechanistic analogues for dibenzothiophene yielded a total of 42 unique candidate analogues: 24 structural analogues and 18 metabolites. None of the identified candidate analogues have inhalation toxicity values from authoritative sources such as U.S. EPA, ATSDR, or CalEPA.

Because no candidate analogues with inhalation toxicity values were identified for dibenzothiophene, the alternative analogue approach was unable to derive screening reference inhalation concentrations for dibenzothiophene.