# 3 DERIVATION OF PROVISIONAL VALUES

## 3.1 DERIVATION OF INHALATION REFERENCE CONCENTRATIONS

No adequate studies were located regarding toxicity of cis-1,2-DCE to humans or animals via inhalation exposure. Chronic (U.S. EPA, 2010) and subchronic (U.S. EPA, 2011c) oral toxicity values based on renal effects in a subchronic rat study are available for cis-1,2-DCE; however, the available PBPK model for cis-1,2-DCE is not suitable for route-to-route extrapolation or estimation of HEDs. As a result of the limitations of the available inhalation toxicity data for cis-1,2-DCE, subchronic and chronic provisional reference concentrations (p-RfCs) were not derived directly. Instead, screening subchronic and chronic p-RfCs are derived in Appendix A using an alternative analogue approach. Based on the overall analogue approach presented in Appendix A, trans-1,2-DCE was selected as the most appropriate analogue for cis-1,2-DCE for deriving screening subchronic and chronic p-RfCs (see Table 4).

## 3.2 SUMMARY OF NONCANCER PROVISIONAL REFERNCE VALUES

Table 4 presents a summary of noncancer references values.

Table 4 Summary of Noncancer Risk Estimates for cis-1,2-DCE (CASRN 156-59-2)^a^

Toxicity Type (units) | Species/Sex | Critical Effect | p-Reference Value | POD Method | POD (HEC) | UF_C_ | Principal Study
Screening subchronic p-RfC (mg/m^3^) | Rat/M | Decreased lymphocyte counts | 4 × 10^−1^ | BMCL_1SD_ | 109 (based on analogue POD) | 300 | Kelly (1998) as cited in U.S. EPA (2020)
Screening chronic p-RfC (mg/m^3^) | Rat/M | Decreased lymphocyte counts | 4 × 10^−2^ | BMCL_1SD_ | 109 (based on analogue POD) | 3,000 | Kelly (1998) as cited in U.S. EPA (2020)

BMCL = benchmark concentration lower confidence limit; cis-1,2-DCE = cis-1,2-dichloroethylene; HEC = human equivalent concentration; M = male(s); NDr = not determined; POD = point of departure; p-RfC = provisional reference concentration; p-RfD = provisional reference dose; SD = standard deviation; UF_C_ = composite uncertainty factor.

## 3.3 CANCER WEIGHT-OF-EVIDENCE DESCRIPTOR

Under the U.S. EPA Cancer Guidelines (U.S. EPA, 2005), there is “Inadequate Information to Assess the Carcinogenic Potential” of cis-1,2-DCE by oral or inhalation exposure (see Table 5).

Table 5 Cancer WOE Descriptor for cis-1,2-DCE (CASRN 156-59-2)

Possible WOE Descriptor | Designation | Route of Entry (oral, inhalation, or both) | Comments
“Carcinogenic to humans” | NS | NA | No human carcinogenicity data were identified to support this descriptor.
“Likely to be carcinogenic to humans” | NS | NA | No human or animal carcinogenicity data were identified to support this descriptor.
“Suggestive evidence of carcinogenic potential” | NS | NA | No human or animal carcinogenicity data were identified to support this descriptor.
“Inadequate information to assess carcinogenic potential” | Selected | Both | This descriptor is selected due to the lack of any studies evaluating carcinogenicity of cis-1,2-DCE.
“Not likely to be carcinogenic to humans” | NS | NA | No evidence of noncarcinogenicity was available.

cis-1,2-DCE = cis-1,2-dichloroethylene; NA = not applicable; NS = not selected; WOE = weight of evidence.

## 3.4 DERIVATION OF PROVISIONAL CANCER RISK ESTIMATES

Table 6 presents a summary of cancer risk estimates. No human or animal studies of carcinogenicity are available for cis-1,2-DCE. Tests for genotoxicity were primarily negative. Thus, the database for cis-1,2-DCE provides inadequate information to assess carcinogenic potential.

Table 6 Summary of Cancer Risk Estimates for cis-1,2-DCE (CASRN 156-59-2)

Toxicity Type | Species/Sex | Tumor Type | Cancer Value | Principal Study
p-OSF (mg/kg-d)^−1^ | NDr
p-IUR (mg/m^3^)^−1^ | NDr

cis-1,2-DCE = cis-1,2-dichloroethylene; NDr = not determined; p-IUR = provisional inhalation unit risk; p-OSF = provisional oral slope factor.