# 2 REVIEW OF POTENTIALLY RELEVANT DATA FOR DERIVATION OF NONCANCER AND CANCER INHALATION REFERENCE VALUES

No short-term, subchronic, or chronic studies; developmental or reproductive toxicity studies; or carcinogenicity studies of cis-1,2-DCE in humans or animals conducted by inhalation exposure were identified.

## 2.1 OTHER DATA (SHORT TERM TESTS, OTHER EXAMINATIONS)

Data for cis-1,2-DCE are limited to a single acute inhalation study, oral studies, injection studies, and studies on 1,2-DCE mixtures containing both the cis- and trans-1,2-DCE isomers. The findings from relevant studies are briefly summarized in the text below. More detailed descriptions of the individual studies are provided in Table 3.

Table 3 Supporting Animal Studies of cis-1,2-DCE^a^

Test | Materials and Methods | Results | Conclusions | References
Supporting studies in animals following inhalation exposure
Acute (cis isomer) | Rats (5/sex/group; strain not specified) were exposed to cis-1,2-DCE vapor concentrations of 0, 12,100, 13,500, 15,700, or 23,200 ppm (equivalent to 0, 47,900, 53,400, 62,200, and 91,900 mg/m^3^) for 4 h. Animals were observed for 14 d. | No deaths occurred at 47,900 mg/m^3^. 4/10 rats died at 53,400 mg/m^3^, and 10/10 animals died in the two highest dose groups.; During exposure, animals were prostrate, with eyes open, and unresponsive to alerting stimulus. Animals that survived exhibited irregular respiration immediately after exposure and slight to severe weight loss for 1 d after exposure. | Rat LC_50_ (4 h) = 13,700 ppm (54,320 mg/m^3^). | DuPont Haskell Lab (1999)
Supporting studies in animals following oral exposure
Acute (cis and trans isomers) | Male Holtzman rats (3−4/group) were administered single oral doses of 0, 400, or 1,500 mg/kg cis-1,2-DCE or trans-1,2-DCE in corn oil via gavage. At 20 h after dosing, liver G6P, tyrosine transaminase and ALP activities, and plasma ALP and ALT activities were measured. | Results for cis isomer: ↑ liver ALP at ≥400 mg/kg; ↓ liver tyrosine transaminase and G6P at 1,500 mg/kg; ↓ plasma ALT at 1,500 mg/kg.; Results for trans isomer: ↑ liver G6P at 400 mg/kg (only); ↓ liver tyrosine transaminase at 1,500 mg/kg. | Limited evidence of liver effects for cis-1,2-DCE at ≥400 mg/kg, unlike trans-1,2-DCE, at 1,500 mg/kg cis-1,2-DCE: ↑ liver ALP, ↓ plasma ALT suggesting that the cis isomer elicits a slightly greater biochemical response than the trans isomer at this dose. | Jenkins et al. (1972)
Acute (cis and trans isomers) | Male Sprague Dawley rats (6/dose) were administered single oral doses of 0, 26, or 51 mmol/kg cis-1,2-DCE (~2,500 or 5,000 mg/kg) by gavage in sesame seed oil. Levels of liver GSH and plasma ALT, AST, and SDH activity were measured after 24 h. | Results for cis isomer: ↑ liver GSH (19 and 28%) and ↑ serum SDH (57 and 56.5%) at 2,500 and 5,000 mg/kg, respectively; ↑ serum AST (56%) at 5,000 mg/kg; no change in serum ALT. Two animals in the 5,000 mg/kg group died.; Results for trans isomers: No significant changes in enzyme levels. One treated animal died. | Limited evidence of liver effects for cis-1,2-DCE at ≥2,500 mg/kg, with no response from trans-1,2-DCE. | Mcmillan (1986), dissertation
Short-term (cis isomer) | Sprague Dawley rats (10/sex/dose) were administered 0, 1.0, 3.0, 10.0, or 20.0 mmol/kg cis-1,2-DCE (~0, 97, 291, 970, and 1,940 mg/kg-d) by gavage for 14 d.; Animals were monitored for mortality, clinical signs of toxicity, food and water intake, serum chemistry, hematology, organ weights, and histopathology. | The percent changes of select endpoints compared with controls in males and females at 97, 291, 970, and 1,940 mg/kg-d, respectively, are reported. Results shown are statistically significant except where noted as NS.; Females:; [underlined: ↑ Absolute liver weight]; 21%, 24%, 35%, 44%; [underlined: ↑ Relative liver weight]; 15%, 18%, 29%, 39%; [underlined: ↑ Absolute kidney weight]; 11% (NS), 11% (NS), 20%, 16%; [underlined: ↑ Relative kidney weight]; 5% (NS), 5% (NS), 14%, 12%; [underlined: ↓ Hematocrit]; 8% (NS), 11%, 11%, 11%; [underlined: ↑ Cholesterol]; 15% (NS), 17% (NS), 25% (NS), 40%; No significant changes in hemoglobin, RBC counts, or plasma AST levels.; Males:; [underlined: ↑ Absolute liver weight]; 12% (NS), 19% (NS), 28%, 26%; [underlined: ↑ Relative liver weight]; 16%, 18%, 33%, 38%; [underlined: ↑ Absolute kidney weight]; 4% (NS), 16% (NS), 21% (NS), 5% (NS); [underlined: ↑ Relative kidney weight]; 7% (NS), 15% (NS), 21% (NS), 15% (NS); ↓ Absolute spleen weight; (7%) in high-dose males. No significant changes in RBC parameters or plasma AST levels. | Limited evidence for an effect on liver (increased organ weights) in males and females at ≥97 mg/kg-d.; Limited evidence for an effect on the kidney (increased organ weights) in females at ≥970 mg/kg-d.; Hematological changes were small in magnitude, not clearly related to dose, and within the normal range of variation (U.S. EPA, 2010). | McCauley et al. (1995); McCauley et al. (1990)
Subchronic (cis isomer) | Sprague Dawley rats (10/sex/dose) were administered 0, 0.33, 1, 3, or 9 mmol/kg-d cis-1,2-DCE (~0, 32, 97, 291, and 872 mg/kg-d) by gavage for 90 d.; Animals were monitored for mortality, clinical signs of toxicity, food and water intake, serum chemistry, hematology, organ weights, and histopathology. | The percent changes of select endpoints in males and females at 32, 97, 291, and 872 mg/kg-d, respectively, are reported. Results shown are statistically significant except where noted as NS.; Females:; [underlined: ↑ Absolute liver weight]; 3% (NS), 11% (NS), 15% (NS), 24%; [underlined: ↑ Relative liver weight]; 3% (NS), 14%, 19%, 30%; [underlined: ↑ Absolute kidney weight]; 3% (NS), 16% (NS), 17% (NS), 17% (NS); [underlined: ↑ Relative kidney weight]; 3% (NS), 20% (NS), 23% (NS), 23% (NS); [underlined: ↓ Hemoglobin]; 3% (NS), 5% (NS), 6%, 4% (NS); [underlined: ↓ Hematocrit]; 4% (NS), 6% (NS), 10%, 8%; [underlined: ↓ RBC counts]; 3% (NS), 4% (NS), 8%, 6% (NS); ↑ Absolute (13%) and ↑ relative (17%) thymus weight in high-dose females.; Males:; [underlined: ↑ Absolute liver weight]; 6% (NS), 13% (NS), 5% (NS), 15% (NS); [underlined: ↑ Relative liver weight]; 11% (NS), 15%, 17%, 32%; [underlined: ↑ Absolute kidney weight]; 9% (NS), 17% (NS), 7% (NS), 14% (NS); [underlined: ↑ Relative kidney weight]; 14%, 19%, 19%, 27%; [underlined: ↓ Hemoglobin]; 5% (NS), 3% (NS), 6%, 6%; [underlined: ↓ Hematocrit]; 6% (NS), 6%, 9%, 9%; No statistically significant changes in RBC counts. | LOAEL = 32 mg/kg-d based on increased relative kidney weights in male rats.; Limited evidence for an effect on liver (increased organ weights) in males and females at ≥97 mg/kg-d.; Hematological changes were small in magnitude, not clearly related to dose, within the normal range of variation (U.S. EPA, 2010), and possibly reflective of increased water intake observed in the treated rats. | McCauley et al. (1995); McCauley et al. (1990)
Supporting studies in animals via other routes
Acute (i.p.) (cis and trans isomers) | Male Sprague Dawley rats (6/dose) were administered single i.p. doses of 0, 21, or 26 mmol/kg cis-1,2-DCE (~2,000 and 2,500 mg/kg) or 0, 20, or 25 mmol/kg trans-1,2-DCE (~1,900 and 2,300 mg/kg) in sesame seed oil. Levels of liver GSH and plasma ALT, AST, and SDH activities were measured after 24 h.; In a separate time-course study performed with 2,500 mg/kg trans-1,2-DCE administered i.p., serum enzyme activities were measured at 2, 4, 8, 12, and 24 h postdosing. Liver histopathology was also characterized. | Results for cis isomer: Dose-related increases in AST and SDH, statistically significant at ≥2,000 mg/kg. No change in GSH. One animal died at the high dose.; Results for trans isomer: Dose-related decrease in liver GSH, significant at 2,300 mg/kg. No significant changes in plasma ALT, AST, or SDH. Two animals died at the high dose.; Results for trans isomer time-course: Plasma ALT, AST, and SDH peaked around 4 h postdosing, returning to near normal by 12 h. Histopathology indicated signs of necrosis. The extent was maximal at 4−8 h, decreasing to 24 h. | Evidence of liver effects (serum chemistry) for cis-1,2-DCE at ≥2,000 mg/kg 24 h postdosing.; Evidence of liver effects (serum chemistry, necrosis) for trans-1,2-DCE at 2,500 mg/kg 4 h postdosing. | Mcmillan (1986), dissertation
Acute (i.p.) (cis and trans isomers) | Wistar rats (4/sex/group) were treated i.p. with 0 or 7.5 mmol/kg (730 mg/kg) of cis- or trans-1,2-DCE for 4 consecutive days. Animals were sacrificed 24 h after the last dose. Body-weight change was recorded, and liver, spleen, and thymus weights were measured. | Results for cis isomer: Statistically significant decreased body-weight gain (−9%) was observed in males but not females; no significant changes in relative liver, spleen, or thymus organ weights in either sex.; Results for trans isomer: Statistically significant decreased body-weight gain (−4%) was observed in males but not females; no significant changes in relative liver, spleen, or thymus organ weights in either sex. | No effect on relative liver weight at 730 mg/kg 24 h after dosing on 4 consecutive days, even with significant decrease in body-weight gain. | Hanioka et al. (1998)
Acute (i.p.) (cis and trans isomers) | Wistar rats (4−6/group) were given single i.p. doses of 0 or 500 mg/kg cis-1,2-DCE or trans-1,2-DCE in corn oil. Initial body weights were measured at the start of the treatment, and body, liver, and lung weights were measured 24 h postdosing. | cis isomer results: Statistically significant loss in body weight occurred in treated animals. An increase in relative liver weight (9.4%) was observed but did not reach statistical significance. No changes in relative lung weights were observed.; trans isomer results: A decrease in body weight and an increase in relative liver weight (11%) were not statistically significant. No changes in relative lung weights were observed. | Marginal increase in relative liver weight at 500 mg/kg 24 h after a single dose of either cis- or trans-1,2-DCE, even with body weights reduced. | Nakahama et al. (2000)
Acute (i.p.) (cis and trans isomers) | Male Swiss mice (10/dose) were administered single i.p. doses of 0, 128, 1,280, or 2,560 mg/kg of cis-1,2-DCE or 0, 1,280, 2,560, or 5,120 mg/kg of trans-1,2-DCE in corn oil. Kidney function was assessed by measuring protein and glucose levels in urine. Histopathological examinations of proximal convoluted tubules were performed in groups of five mice at the mid dose. | 4/10 (cis isomer) and 5/10 (trans isomer) animals died in the high-dose groups. Deaths occurred within 24 h and appeared to be due to narcosis. In the low-, mid-, and high-dose groups, 2/10, 2/10, and 3/6 (cis isomer) and 0/10, 1/10, and 3/5 (trans isomer) surviving animals, respectively, had increased urinary protein (≥100 mg% of protein, as indicated by a Combistix standard color chart). In controls, 32/60 had no protein, 23/60 had trace amounts of protein, 5/60 had 30 mg%, and 0/60 had 100 mg%. None of the treated mice or controls had elevated glucose. No swelling or necrosis of the proximal convoluted tubules was observed (0/5 mice) for either isomer at the mid dose. | The study authors considered these results to show limited evidence of nephrotoxicity for cis-1,2-DCE or trans-1,2-DCE. | Plaa and Larson (1965)
Supporting mixture studies
Short-term (inhalation) (mixture [58% cis, 42% trans isomer]) | Rats (10/sex) were exposed whole body to a 1,2-DCE vapor concentration of 1,000 ppm (~1,980 mg/m^3^) for 7 h/d, 5 d/wk for 14 d. Untreated and air-only control groups were included. Endpoints included body weights, select organ weights, serum chemistry (BUN, ALP, ALT), and hematology. | ↑ Relative kidney (males, 6.4%) and liver weights (both sexes <5%). | Limited evidence for an effect on the liver and kidney (increased organ weights) at 1,980 mg/m^3^. | Dow Chemical (1994)
Subchronic (inhalation) (mixture [58% cis, 42% trans isomer]) | Rats (24−35 at low dose; 12/sex at high dose) were exposed whole body to 1,2-DCE vapor concentrations of 500 or 1,000 ppm (~1,980 or 3,970 mg/m^3^) for 7 h/d, 5 d/wk for 6 mo. Untreated and air-only control groups were included. Endpoints included body weights, select organ weights, serum chemistry (BUN, ALP, ALT), and hematology. | ↑ Relative kidney weights in males (9 and 16%) at 1,980 and 3,960 mg/m^3^. Relative kidney weights in females were increased by 18 and 9%, respectively, but were not statistically significant.; ↑ Relative liver weights (19 and 23%, females only) at both exposure levels. | Limited evidence of liver and kidney effects (increased organ weights) at 1,980 mg/m^3^. | Dow Chemical (1994)
Short-term (oral) (mixture [50:50]) | Male Sprague Dawley rats (6/group) were administered 0 or 5 mmo1/kg-d (equivalent to approximately 485 mg/kg-d) of a 50:50 mixture of cis- and trans-1,2-DCE by gavage in sesame seed oil for 14 d. Endpoints included body weights, food consumption, hematology, clinical chemistry, select organ weights, and histopathology; liver GSH analysis was performed. | ↑ Relative kidney weights (13%).; No significant changes in RBC or other hematology parameters. No clinical chemistry or histopathology findings. | Limited evidence of kidney effect (increased kidney weight). | Mcmillan (1986), dissertation
Subchronic (oral) (mixture [50:50]) | Male Sprague Dawley rats (6/group) were administered 0 or 5 mmo1/kg-d (equivalent to approximately 485 mg/kg-d) of a 50:50 mixture of cis- and trans-1,2-DCE by gavage in sesame seed oil for 30 d. Endpoints included body weights, food consumption, hematology, clinical chemistry, select organ weights, and histopathology; liver GSH analysis was performed. | ↑ Relative liver weight (19%), ↑ relative lung weight (14%), ↓ RBC (6%), ↓ hemoglobin (5%), and ↓ hematocrit (5%).; No effect on relative kidney weight. No biologically significant changes in serum chemistry. No histopathology was observed. | Limited evidence of effect on liver (increased organ weight). | Mcmillan (1986), dissertation

a Several studies conducted experiments on both cis- and trans-1,2-DCE isomers. When appropriate, results for both isomers are reported.

↑ = statistically significantly increased; ↓ = statistically significantly decreased; ALP = alkaline phosphatase; ALT = alanine aminotransferase; AST = aspartate aminotransferase; BUN = blood nitrogen urea; cis-1,2-DCE = cis-1,2-dichloroethylene; G6P = glucose-6-phosphate; GSH = glutathione; i.p. = intraperitoneal; LC_50_ = median lethal concentration; NS = not statistically significant; RBC = red blood cell; SDH = sorbitol dehydrogenase; trans-1,2-DCE = trans-1,2-dichloroethylene.

### 2.1.1 Supporting Animal Studies

#### Inhalation Studies (Acute)

The only available inhalation study on cis-1,2-DCE is a lethality study reporting a 4-hour median lethal concentration (LC_50_) in rats of 54,320 mg/m^3^ (DuPont Haskell Lab, 1999).

#### Oral Studies (Acute)

Two studies, one detailed in a dissertation (Mcmillan, 1986), were located in which rats were administered single gavage doses (ranging from 400 to 5,000 mg/kg) of cis-1,2-DCE or trans-1,2-DCE and evaluated for serum markers of liver toxicity (e.g., serum alkaline phosphatase [ALP], aspartate aminotransferase [AST], alanine aminotransferase [ALT]) and liver enzyme activities (e.g., glucose-6-phosphatase, tyrosine transaminase, and glutathione [GSH]) (Mcmillan, 1986; Jenkins et al., 1972). Both studies reported evidence of liver toxicity following dosing with cis-1,2-DCE, with a greater response in animals dosed with cis-1,2-DCE compared with the trans isomer.

#### Oral Studies (Short-Term and Subchronic Studies)

McCauley et al. (1990) and McCauley et al. (1995) conducted 14- and 90-day gavage studies in Sprague Dawley rats; these are the only short-term and subchronic oral studies available for cis-1,2-DCE. The unpublished report described in McCauley et al. (1990) was subsequently published as McCauley et al. (1995). Although errors in the documentation of doses and other minor inconsistencies were noted between the two documents, they were not considered to compromise the reliability of the findings and doses presented herein were confirmed by the study authors.^2^

In the short-term gavage study (McCauley et al., 1995; McCauley et al., 1990), Sprague Dawley rats (10/sex/dose) were administered cis-1,2-DCE in corn oil (at doses of 0, 97, 291, 970, or 1,940 mg/kg-day) for 14 days; doses as reported by U.S. EPA (2010). Several gavage-related deaths (2/10 males and 3/10 females) and clinical signs, including excessive clear secretions about the nose and/or mouth and agitation followed by lethargy and ataxia, were reported at the 1,940 mg/kg-day dose level. At the high dose, male body weights were significantly reduced by approximately 10%. Compared with controls, significant increases in water consumption were observed, particularly in the highest dose groups (20−35% higher), and water consumption per body weight was significantly increased for females in all treatment groups and for males at 1,940 mg/kg-day. The main observed effects included statistically significant, dose-related increases in relative liver weights in both sexes (males: 16−38%; females 15−39%) and increased absolute liver weights in females in all dose groups (by 21−44%) and in males at 970 and 1,940 mg/kg-day (by 28 and 26%, respectively). Relative and absolute kidney weights were statistically significantly increased in females at 970 and 1,940 mg/kg-day (by 14 and 12% and by 20 and 16%, respectively), but the increases were not dose-related. No statistically significant increases in kidney weights were observed in males, although increases were >10% in magnitude in several dose groups. In high-dose males, absolute spleen weights were statistically significantly decreased from control by approximately 7%. Supporting clinical chemistry changes were limited to significantly increased cholesterol levels (by 25−40%) in both males and females in the highest dose groups. There were no statistically significant changes in plasma AST levels. Serum ALT and lactate dehydrogenase (LDH) levels were also measured, but the results were not reported in the study. Other serum chemistry changes (blood urea nitrogen [BUN], creatinine, phosphorus, calcium, and glucose) were generally small in magnitude, not dose-related, or not consistent between sexes. Hematocrit levels in females were statistically significantly decreased in the three highest dose groups, but the changes were small (11%) and did not increase with dose. No significant changes in hemoglobin or red blood cell (RBC) counts were observed; no other significant hematological changes (i.e., white blood cell [WBC] counts) were observed in females and no statistically significant hematological changes were observed in males. No gross or histopathological findings accompanying any organ-weight changes were observed.

In the 90-day study, groups of Sprague Dawley rats (10/sex/dose) were administered cis-1,2-DCE in corn oil via gavage at doses of 0, 32, 97, 291, or 872 mg/kg-day^3^ for 90 days (McCauley et al., 1995; McCauley et al., 1990); doses as reported by U.S. EPA (2010). No compound-related deaths or clinical signs were observed, but an increase in water intake (as a percentage of body weight) occurred at the higher dose levels. Reductions in male body weights (10−11%) at 291 and 872 mg/kg-day did not reach statistical significance. Similar to the 14-day study, the liver and kidney were identified as main target organs. Relative liver weights were statistically significantly increased over controls in a dose-related manner in both sexes (by 3−32%), and absolute liver weights were significantly increased in high-dose females (by 24%). Absolute liver weights in males were not significantly different from controls. Relative kidney weights in males were significantly increased, compared with controls, in all dose groups (by 14−27%). Increased relative kidney weights in females and absolute kidney weight changes in both sexes were not statistically significant, but the magnitudes of change were >10% in most dose groups (see Table 3). In high-dose females, absolute and relative thymus weights were statistically significantly increased, compared with controls (by 13 and 17%, respectively). Statistically significant clinical chemistry changes were sporadic or not adverse. In females, hemoglobin and RBC levels were significantly decreased (by 6 and 8%, respectively) at 291 mg/kg-day (but not in the high-dose group), and reduced hematocrit levels (by 10 and 8%, respectively) were measured at 291 and 872 mg/kg-day. In males, significant decreases in hemoglobin occurred in the 291 and 872 mg/kg-day groups and hematocrit levels were decreased in the 97, 291, and 872 mg/kg-day groups. However, the changes were small (6−9% decreases) and not clearly related to dose (see Table 3). An analysis by U.S. EPA (2010) showed that the observed values were within the normal range of variation. These endpoints could have been affected by increased water intake observed in the higher dose groups. No treatment-related gross or histological lesions were observed. Increased relative kidney weight in male rats was selected as the critical effect for deriving the subchronic provisional reference dose (p-RfD) for cis-1,2-DCE in the PPRTV assessment and the chronic reference dose (RfD) in the cis-1,2-DCE IRIS assessment (see Table 2 and Table A-7) (U.S. EPA, 2011c, 2010).

#### Injection Studies

An acute injection study in rats reported in a dissertation (Mcmillan, 1986) showed dose-related increases in plasma AST and sorbitol dehydrogenase (SDH) activities 24 hours after single intraperitoneal (i.p.) injections of 0, ∼2,000, and 2,500 mg/kg cis-1,2-DCE. Although a single i.p. dose of ∼1,900 and 2,300 mg/kg trans-1,2-DCE did not show effects at 24 hours, time-course experiments performed with 2,500 mg/kg of the trans isomer as part of the same study did show the following effects: serum ALT, AST, and SDH activities peaked 4 hours postdosing, subsequently declining to near-normal levels; necrosis also was observed (maximal at 4−8 hours). Nakahama et al. (2000) found only marginal nonsignificant increases in relative liver weights (by 9.4−11%) in rats 24 hours after a single 500 mg/kg i.p. injection of either cis- or trans-1,2-DCE, even though body weights were reduced by both isomers. Similarly, there was no effect on relative liver weight in rats injected on 4 consecutive days with 730 mg/kg of either cis- or trans-1,2-DCE, despite significant decreases in body-weight gain with both isomers (Hanioka et al., 1998). Mice injected with 128−5,120 mg/kg of cis- or trans-1,2-DCE showed weak nephrotoxicity (increased urinary protein) in a study that also assessed urinary glucose levels and included histopathological examinations of proximal convoluted tubules (Plaa and Larson, 1965).

#### Mixture Studies

Several studies on 1,2-DCE mixtures containing both the cis and trans isomer are reviewed in U.S. EPA (2010). In many cases, the isomer compositions were not reported or were unknown, making the determination of the potential contribution of the cis isomer to the observed effects difficult. Select studies where compositions were reported are detailed in Table 3. In general, mixture studies (both inhalation and oral) identify the liver and kidney as primary target organs, which is consistent with observations from studies on the cis- and trans-1,2-DCE isomers alone. In an unpublished report, Dow Chemical (1994) performed a series of inhalation experiments using a 1,2-DCE mixture composed of 58% cis-1,2-DCE and 42% trans-1,2-DCE in rats (rabbits, guinea pigs, and beagle dogs were also tested, but group sizes were small and no statistical analysis was done) (U.S. EPA, 2010). This included a preliminary 14-day study, followed by a 6-month inhalation study in which rats were exposed to 1,2-DCE vapor concentrations of 0, 500, or 1,000 ppm (equivalent to ∼1,980 or 3,970 mg/m^3^). In the 6-month study, exposure concentration-related increases in relative kidney weights (by 9 and 16%) in males and relative liver weights (by 19 and 23%) in females at 1,980 and 3,970 mg/m^3^, respectively, were statistically significant. In an oral mixture study described in a dissertation (Mcmillan, 1986), a statistically significant increase in relative kidney weights (by 13%) was reported in male Sprague Dawley rats administered 485 mg/kg-day 1,2-DCE (a 50:50 mixture of cis- and trans-1,2-DCE) via gavage for 14 days. In a follow-up 30-day study at the same dose, relative liver weights in the treatment group were significantly increased by 19%, compared with controls (Mcmillan, 1986).

### 2.1.2 Genotoxicity

The genotoxicity of cis-1,2-DCE has been evaluated in numerous in vitro studies and in a limited number of in vivo assays in both mammalian and nonmammalian systems summarized in U.S. EPA (2010). No new genotoxicity studies on cis-1,2-DCE were identified. Overall cis-1,2-DCE is generally negative for genotoxicity. cis-1,2-DCE was negative in six reverse mutation studies in Salmonella typhimurium and two studies for deoxyribonucleic acid (DNA) damage in Escherichia coli. Results from gene conversion, reverse mutation, or mitotic recombination studies in Saccharomyces cerevisiae were mixed. One study reported positive results in S. cerevisiae D7 both with and without metabolic activation, but results were negative in three other studies (U.S. EPA, 2010). No chromosomal aberrations or evidence of sister chromatid exchange (SCE) were observed in Chinese hamster lung (CHL) cells, with or without activation, in two separate studies. Negative results were also reported for chromosomal aberrations (CAs) in one study in Chinese hamster ovary (CHO) cells, but results were inconclusive for SCE in this study. In vivo, cis-1,2-DCE was mutagenic in two of three available host-mediated assays in mice, produced CAs in one of two available mouse bone marrow assays, and was negative for SCE. Additional details can be found in the U.S. EPA (2010) IRIS toxicological review for cis-1,2-DCE.

### 2.1.3 Metabolism/Toxicokinetic Studies

Experimental data show inhaled cis-1,2-DCE to be well-absorbed through the lungs, a result consistent with the blood-air partition coefficients estimated in humans and rats for this chemical (9.2−9.8 and 21.6, respectively) (Gargas et al., 1989). Closed-chamber gas uptake studies in rats indicate an initial first phase of gas uptake to equilibrium that took approximately 2 hours and left approximately 50% of the gas remaining in the chamber (Filser and Bolt, 1979). Further uptake was dependent on the velocity of metabolism and showed a logarithmic (first-order) decline in chamber levels of cis-1,2-DCE when the initial exposure concentration was low (500 ppm). At a higher exposure concentration (1,000 ppm), equilibrium is followed by a phase showing a linear (zero-order) decline, suggesting saturation of metabolism at the higher concentrations. The equilibrium constant K_eq_ for cis-1,2-DCE is 20, approximately double that for the trans isomer (K_eq_ = 11.5), indicating that uptake of cis-1,2-DCE is ∼2-fold higher, which is consistent with the rodent blood-gas partition coefficients of 21.6 and 9.58 for cis- and trans-1,2-DCE, respectively (Filser and Bolt, 1979; Bonse et al., 1975). No studies quantifying the rate or extent of cis-1,2-DCE uptake following oral or dermal exposure were located.

No studies were identified that investigated the tissue distribution of cis-1,2-DCE in the body. Tissue:air partition coefficients determined for rat tissues ex vivo were 15.3 for liver, 6.09 for muscle, and 227 for fat (Gargas et al., 1988), suggesting that cis-1,2-DCE in the blood will be distributed to the liver and will accumulate preferentially in fat.

Studies in vitro using liver microsomes indicate that metabolism of cis-1,2-DCE is initiated upon the binding of cis-1,2-DCE to the heme moiety of hepatic microsomal cytochrome P450s (CYP450s) (Costa and Ivanetich, 1984, 1982). Upon activation, presumably by CYP2E1 (in hepatic tissue), cis-1,2-DCE is metabolized to an unstable epoxide intermediate that rearranges to form 2,2-dichloracetaldehyde, which is enzymatically converted to 2,2-dichloroethanol and 2,2-dichloroacetic acid (DCA) by alcohol dehydrogenase (Nakajima, 1997; Costa and Ivanetich, 1984; Henschler and Bonse, 1979; Bonse et al., 1975). 2,2-Dichloroethanol appears to be the major metabolite, with smaller amounts of DCA formed (Costa and Ivanetich, 1984; Bonse et al., 1975). The rate of cis-1,2-DCE metabolite production appears to be faster and the total amount of metabolites produced is greater than for the trans isomer (by approximately 4−25 times) (Costa and Ivanetich, 1984). Although CYP2E1 is likely the primary CYP450 responsible for cis-1,2-DCE metabolism, other CYP450s could also be involved. For example, in vitro inhibition studies by Costa and Ivanetich (1984) indicated that cytochrome P448, which is induced by β-naphthoflavone, appeared to play a slight, but significant, role in the binding and metabolism of cis-1,2-DCE. Studies indicate that both cis- and trans-1,2-DCE (or their metabolites) can inhibit CYP450 enzymes via irreversible binding (i.e., suicide inactivation), with trans-1,2-DCE overall being the more potent inhibitor (U.S. EPA, 2008; Nakahama et al., 2000; Hanioka et al., 1998; Lilly et al., 1998; Mathews et al., 1998; Barton et al., 1995; Clewell and Andersen, 1994; Costa and Ivanetich, 1984; Freundt and Macholz, 1978, 1972). The irreversible binding is anticipated to result in competitive inhibition of the metabolism of other CYP450 substrates in vitro. The zero-order turnover velocity (V_max_) of cis-1,2-DCE was determined to be 2.4 mg/hour-kg (Filser and Bolt, 1979). The V_max_ was later determined to be 3.0 mg/hour-kg by Gargas et al. (1988) and to be 3.34 mg/hour-kg after compensating for enzyme inhibition and resynthesis (Gargas et al., 1990). Metabolic rates increased under conditions of fasting or chronic ethanol intake (Nakajima, 1997).

Data on the elimination of cis-1,2-DCE are limited. Biphasic elimination with an initial rapid elimination from blood followed by a second, only slightly slower, phase of elimination from highly perfused tissues was suggested from a single study in humans (Pleil and Lindstrom, 1997). Elimination rate constants based on concentrations in exhaled breath over time were estimated for two volunteers exposed in a 10-minute shower to cis-1,2-DCE from contaminated well water (exposure concentrations were 20.4−28.4 μg/L and 84−125 μg/m^3^ measured in water and air, respectively). The elimination half-lives, corresponding to the two phases of elimination were 0.82 and 8.96 minutes, respectively, in the first volunteer, and 2.37 and 29.33 minutes, respectively, in the second volunteer (Pleil and Lindstrom, 1997). Elimination of the metabolite, DCA, has not been specifically evaluated in the context of exposure to cis-1,2-DCE but the downstream metabolism of DCA and subsequent elimination have been reviewed in the Toxicological Review of Dichloroacetic Acid (U.S. EPA, 2003). DCA is ultimately expected to be metabolized to produce glyoxylate that can be further processed to form oxalate, which is excreted in urine or reduced to form glycolic acid. DCA can also be broken down into carbon dioxide (Costa and Ivanetich, 1984, 1982). Trace amounts of 2,2-dichloroethanol are expected to be ultimately exhaled (U.S. EPA, 2010).

A physiologically based pharmacokinetic (PBPK) model is available for inhaled cis-1,2-DCE in rats, as described in U.S. EPA (2010), but does not include a compartment to account for oral exposure and has not been extended to humans. U.S. EPA (2010) concluded that “Since this PBPK model was not calibrated with human data, it cannot be scaled allometrically to humans, whose liver CYP2E1 activity, resynthesis rate, and sensitivity to inhibition differ from those in rats. Given the current state of knowledge, this PBPK model is not useful for estimating the human equivalent dose (HED) from the available animal data for cis- or trans-1,2-DCE.” Because oral exposure is not accounted for, the model cannot be used for route-to-route extrapolation.

2 Doses in the McCauley et al. (1995) study were incorrectly reported and converted from mmol/kg-day to mg/kg-day. In addition, the doses for the acute- and subchronic study as presented in the 1995 published paper were reversed (i.e., the doses listed for the 14-day study are for the 90-day study and vice-versa). The doses presented here reflect the correctly converted doses (confirmed by the study author) (U.S. EPA, 2010).

3 The administered doses in McCauley et al. (1995) were reported as 0, 0.33, 1, 3, and 9 mmol/kg-day that, when converted to mg/kg-day, are 0, 32, 97, 291, and 872 mg/kg-day, respectively. McCauley et al. (1995), however, reported the converted doses incorrectly as 0, 10, 32, 98, and 206 mg/kg-day. The doses presented here are the correctly calculated doses of doses of 0, 32, 97, 291, and 872 mg/kg-day, as reported in McCauley et al. (1990) (confirmed by the study author) (U.S. EPA, 2010).