# 1 INTRODUCTION

cis-1,2-Dichloroethylene (cis-1,2-DCE; CASRN 156–59-2) belongs to the class of compounds known as halogenated alkenes. cis-1,2-DCE is an isomer of dichloroethylene. Mixtures of cis-1,2-DCE with its isomer, trans-1,2-dichloroethylene (trans-1,2-DCE), have several commercial uses. 1,2-DCE mixtures are used in the production of other chlorinated compounds and for solvent vapor and surface cleaning (Dreher et al., 2014; Mertens, 2000; ATSDR, 1996). 1,2-DCEs are also used as foam blowing additives, as refrigerants, and in silicone etching (Dreher et al., 2014). Other reported uses of 1,2-DCEs include low temperature solvent extraction for organic materials such as waxes, resins, dyes, perfumes, lacquers, and thermoplastics and extraction of oil and fats from fish and meat (Dreher et al., 2014; Mertens, 2000). cis-1,2-DCE can be produced directly by chlorinating acetylene (Mertens, 2000). 1,2-DCEs are also produced as a byproduct of chlorinated compound production (Mertens, 2000). cis-1,2-DCE is listed on the U.S. EPA nonconfidential Toxic Substances Control Act (TSCA) inventory (U.S. EPA, 2021c) and is registered with Europe’s Registration, Evaluation, Authorisation and Restriction of Chemicals (REACH) program (ECHA, 2020).

The empirical formula for cis-1,2-DCE is C_2_H_2_Cl_2_, and its structure is shown in Figure 1. Table 1 summarizes the physicochemical properties of cis-1,2-DCE. cis-1,2-DCE is a clear, colorless liquid with a sharp, ether-like odor (NLM, 2021g; ATSDR, 1996). Given its high vapor pressure, cis-1,2-DCE is expected to exist solely as a vapor in the atmosphere. Its vapor pressure and moderate Henry’s law constant indicate that it will likely volatilize from either dry or moist soil surfaces and from water surfaces. The high water solubility and low soil adsorption coefficient indicate that cis-1,2-DCE will have the potential to leach to groundwater or undergo runoff after a rain event.

Figure 1 cis-1,2-DCE (CASRN 156–59-2) Structure

Cis-1,2-DCE(CASRN 156-59-2) Chemical Structure

Table 1 Physicochemical Properties of cis-1,2-DCE (CASRN 156-59-2)

Property (unit) | Value^a^
Molecular formula (unitless) | C_2_H_2_Cl_2_
Molecular weight (g/mol) | 96.94
Physical state | Liquid^b^
Physical properties | Clear, colorless, ether-like odor
Boiling point (°C) | 54.4
Melting point (°C) | −64.9
Density (g/cm^3^ at 20°C) | 1.24 (predicted)
Vapor density (at boiling point and 760 mm Hg) | 3.54 g/L^b^
Vapor pressure (mm Hg) | 200^b^
Water solubility (mol/L) | 0.0493
Log K_ow_ | 1.86
pKa (unitless) | NA
Henry’s law constant (atm-m^3^/mole) | 0.00673
Flash point (°C) | 10.3 (predicted)
Auto flammability (°C) | 460^b^
Viscosity (cp at 20°C) | 0.456
Refractive index (at 25°C/D) | 1.45 (predicted)
Dielectric constant | NA

a Data were extracted from the U.S. EPA CompTox Chemicals Dashboard (cis-1,2-dichloroethylene, CASRN 156-59-2. https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID2024030. Accessed on May 12, 2021). All values are experimental averages unless otherwise specified.

b Data are from NLM (2021g).

cis-1,2-DCE = cis-1,2-dichloroethylene; NA = not applicable; U.S. EPA = U.S. Environmental Protection Agency.

A summary of available toxicity values for cis-1,2-DCE from U.S. EPA and other agencies/organizations is provided in Table 2.

Table 2 Summary of Available Toxicity Values for cis-1,2-DCE (CASRN 156-59-2)

Source/Parameter^a,b^ | Value (applicability) | Notes | Study Observing Critical Effect | Reference
Noncancer
IRIS (RfC) | NV | Information reviewed but value not derived | | U.S. EPA (2010)
IRIS (RfD) | 0.002 mg/kg-d | Based on increased relative kidney weight in male rats | McCauley et al. (1995); McCauley et al. (1990) | U.S. EPA (2010)
PPRTV (subchronic p-RfD) | 0.02 mg/kg-d | Based on increased relative kidney weight in male rats | McCauley et al. (1995); McCauley et al. (1990) | U.S. EPA (2011c)
DWSHA (RfD) | 0.002 mg/kg-d | NA | | U.S. EPA (2018a)
HEAST (subchronic RfD) | NV | NA | | U.S. EPA (2011b)
ATSDR (MRL, oral acute) | 1 mg/kg-d | Based on decreased RBC counts and hematocrit levels in female rats exposed for 14 d | McCauley et al. (1990) | ATSDR (1996)
ATSDR (MRL, oral intermediate) | 0.3 mg/kg-d | Based on decreased hematocrit levels in male rats and decreased hemoglobin levels in rats of both sexes exposed for 90 d | McCauley et al. (1990) | ATSDR (1996)
CalEPA (ADD) | 0.00125 mg/kg-d | Based on increased relative kidney weights in male rats exposed for 90 d | McCauley et al. (1995) | CalEPA (2018)
AEGL (AEGL-1) | 10 min: 140 ppm; 30 min: 140 ppm; 60 min: 140 ppm; 4 h: 140 ppm; 8 h: 140 ppm | Based on ocular irritation in humans | Lehmann and Schmidt-Kehl (1936) | U.S. EPA (2018b, 2008)
AEGL (AEGL-2) | 10 min: 500 ppm; 30 min: 500 ppm; 60 min: 500 ppm; 4 h: 340 ppm; 8 h: 230 ppm | Based on narcosis in rats (4 and 8 h) or anesthetic effects in humans (10, 30, and 60 min) | Hurtt et al. (1993) | U.S. EPA (2018b, 2008)
AEGL (AEGL-3) | 10 min: 850 ppm; 30 min: 850 ppm; 60 min: 850 ppm; 4 h: 620 ppm; 8 h: 310 ppm | Based on a no-effect level for death in rats (4 and 8 h) or dizziness, intracranial pressure, and nausea in humans (10, 30, and 60 min) | Kelly (1999) | U.S. EPA (2018b, 2008)
ACGIH (TLV-TWA)^c^ | 200 ppm | Based on CNS impairment and eye irritation | Lehmann and Schmidt-Kehl (1936) | ACGIH (2020)
OSHA (PEL)^c^ | 200 ppm (790 mg/m^3^) | 8-h TWA for general industry, construction, and shipyard employment | | OSHA (2020a, 2020b, 2020c)
NIOSH (REL)^c^ | 200 ppm (790 mg/m^3^) | TWA for up to a 10-h workday during a 40-h workweek | | NIOSH (2019)
NIOSH (IDLH)^c^ | 1,000 ppm | Based on acute inhalation toxicity data in humans | von Oettingen (1955, 1937) | NIOSH (2019, 2014)
Cancer
IRIS (WOE) | Inadequate information to assess carcinogenic potential | NA | | U.S. EPA (2010)
DWSHA (WOE) | Inadequate information to assess carcinogenic potential | NA | | U.S. EPA (2018a)
HEAST | NV | NA | | U.S. EPA (2011b)
NTP | NV | NA | | NTP (2016)
IARC | NV | NA | | IARC (2021)
CalEPA | NV | NA | | CalEPA (2021)
ACGIH^c^ | NV | NA | | ACGIH (2020)

a Sources: ACGIH = American Conference of Governmental Industrial Hygienists; ATSDR = Agency for Toxic Substances and Disease Registry; CalEPA = California Environmental Protection Agency; DWSHA = Drinking Water Standards and Health Advisories; HEAST = Health Effects Assessment Summary Tables; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PPRTV = Provisional Peer-Reviewed Toxicity Value.

b Parameters: ADD = acceptable daily dose; AEGL = acute exposure guideline level; IDLH = immediately dangerous to life or health concentrations; MRL = minimum risk level; PEL = permissible exposure level; p-RfD = provisional reference dose; REL = recommended exposure limit; RfC = reference concentration; RfD = reference dose; TLV = threshold limit value; TWA = time-weighted average; WOE = weight of evidence.

c Values are for 1,2-dichloroethylene (unspecified mixed isomer) and are not specific for 1,2-cis-DCE.

d McCauley et al. (1990) (unpublished report) was subsequently published as McCauley et al. (1995).

cis-1,2-DCE = cis-1,2-dichloroethylene; CNS = central nervous system; NA = not applicable; NV = not available; RBC = red blood cell.

Non-date-limited literature searches were conducted in October 2017 and updated most recently in July 2022 for studies relevant to the derivation of provisional toxicity values for cis-1,2-DCE (CASRN 156–59-2). Searches were conducted using U.S. EPA’s Health and Environmental Research Online (HERO) database of scientific literature. HERO searches the following databases: PubMed, TOXLINE^1^ (including TSCATS1), and Web of Science. The following additional resources were searched outside of HERO for health-related values: American Conference of Governmental Industrial Hygienists (ACGIH), Agency for Toxic Substances and Disease Registry (ATSDR), California Environmental Protection Agency (CalEPA), Defense Technical Information Center (DTIC), European Centre for Ecotoxicology and Toxicology of Chemicals (ECETOC), European Chemicals Agency (ECHA), U.S. EPA Chemical Data Access Tool (CDAT), U.S. EPA ChemView, U.S. EPA Integrated Risk Information System (IRIS), U.S. EPA Health Effects Assessment Summary Tables (HEAST), U.S. EPA Office of Water (OW), International Agency for Research on Cancer (IARC), U.S. EPA TSCATS2/TSCATS8e, U.S. EPA High Production Volume (HPV), Chemicals via International Programme on Chemical Safety (IPCS) INCHEM, Japan Existing Chemical Data Base (JECDB), Organisation for Economic Co-operation and Development (OECD) Screening Information Data Sets (SIDS), OECD International Uniform Chemical Information Database (IUCLID), OECD HPV, National Institute for Occupational Safety and Health (NIOSH), National Toxicology Program (NTP), Occupational Safety and Health Administration (OSHA), and World Health Organization (WHO).

1 Note that this version of TOXLINE is no longer updated (https://www.nlm.nih.gov/databases/download/toxlinesubset.html); therefore, it was not included in the literature search update from July 2022.