# APPENDIX B REFERENCES

ACGIH (American Conference of Governmental Industrial Hygienists). (2020). 1,2-Dichloroethylene, all isomers (156-59-2; 156-60-5; 540-59-0) [TLV/BEI]. In 2020 TLVs and BEIs: Based on the documentation of the threshold limit values for chemical substances and physical agents & biological exposure indices (pp. 26). Cincinnati, OH. https://portal.acgih.org/s/store#/store/browse/detail/a154W00000BOag6QAD
Anders MW. (1985). Bioactivation of foreign compounds. New York, NY: Academic Press.
Arito H; Takahashi M; Ishikawa T. (1994). Effect of subchronic inhalation exposure to low-level trichloroethylene on heart rate and wakefulness-sleep in freely moving rats. Sangyo Igaku 36: 1–8.8126932
Astrand I; Ovrum P. (1976). Exposure to trichloroethylene I. Uptake and distribution in man. Scand J Work Environ Health 2: 199–211.1019594
ATSDR (Agency for Toxic Substances and Disease Registry). (1996). Toxicological profile for 1,2-dichloroethene [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/ToxProfiles/tp87.pdf
ATSDR (Agency for Toxic Substances and Disease Registry). (2006). Toxicological profile for vinyl chloride [ATSDR Tox Profile]. Atlanta, GA. http://www.atsdr.cdc.gov/toxprofiles/tp.asp?id=282&tid=51
ATSDR (Agency for Toxic Substances and Disease Registry). (2019a). Toxicological profile for 1,1-dichloroethene: draft for public comment [ATSDR Tox Profile]. Atlanta, GA. https://www.atsdr.cdc.gov/ToxProfiles/tp39.pdf
ATSDR (Agency for Toxic Substances and Disease Registry). (2019b). Toxicological profile for tetrachloroethylene [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services. https://www.atsdr.cdc.gov/ToxProfiles/tp18.pdf
ATSDR (Agency for Toxic Substances and Disease Registry). (2019c). Toxicological profile for trichloroethylene [ATSDR Tox Profile]. Atlanta, GA. https://www.atsdr.cdc.gov/ToxProfiles/tp19.pdf
Barton HA; Creech JR; Godin CS; Randall GM; Seckel CS. (1995). Chloroethylene mixtures: Pharmacokinetic modeling and in vitro metabolism of vinyl chloride, trichloroethylene, and trans-1,2-dichloroethylene in rat. Toxicol Appl Pharmacol 130: 237–247. 10.1006/taap.1995.1029 7871537
Bi WF; Wang YS; Huang MY; Meng DS. (1985). Effect of vinyl chloride on testis in rats. Ecotoxicol Environ Saf 10: 281–289. 10.1016/0147-6513(85)90074-0 4092642
Bingham E; Cohrssen B. (2012). Patty's toxicology (6th ed.). Hoboken, NJ: John Wiley & Sons.
Bolt HM; Kappus H; Buchter A; Bolt W. (1976). Disposition of [1,2–14C] vinyl chloride in the rat. Arch Toxicol 35: 153–162.989287
Bolt HM; Laib RJ; Kappus H; Buchter A. (1977). Pharmacokinetics of vinyl chloride in the rat. Toxicology 7: 179–188.857343
Bonse G; Urban T; Reichert D; Henschler D. (1975). Chemical reactivity, metabolic oxirane formation and biological reactivity of chlorinated ethylenes in the isolated perfused rat liver preparation. Biochem Pharmacol 24: 1829–1834. 10.1016/0006-2952(75)90468-2 1233985
Boverhof DR; Krieger SM; Hotchkiss J; Stebbins KE; Thomas J; Woolhiser MR. (2013). Assessment of the immunotoxic potential of trichloroethylene and perchloroethylene in rats following inhalation exposure. J Immunotoxicol 10: 311–320. 10.3109/1547691X.2012.735275 23167264
Brodkin CA; Daniell W; Checkoway H; Echeverria D; Johnson J; Wang K; Sohaey R; Green D; Redlich C; Gretch D. (1995). Hepatic ultrasonic changes in workers exposed to perchloroethylene. Occup Environ Med 52: 679–685.7489059
Byczkowski JZ; Fisher JW. (1994). Lactational transfer of tetrachloroethylene in rats. Risk Anal 14: 339–349. 10.1111/j.1539-6924.1994.tb00250.x 8029506
Cai SX; Huang MY; Chen Z; Liu YT; Jin C; Watanabe T; Nakatsuka H; Seiji K; Inoue O; Ikeda M. (1991). Subjective symptom increase among dry-cleaning workers exposed to tetrachloroethylene vapor. Ind Health 29: 111–121. 10.2486/indhealth.29.111 1765547
CalEPA (California Environmental Protection Agency). (2018). Cis- and trans-1,2-dichloroethylene in drinking water. Pesticide and Environmental Toxicology Branch, Office of Environmental Health Hazard Assessment, California Environmental Protection Agency. https://oehha.ca.gov/media/downloads/water/chemicals/phg/phg12-dce072018.pdf
CalEPA (California Environmental Protection Agency). (2021). OEHHA chemical database: 1,2-dichloroethylene, cis. Office of Environmental Health Hazard Assessment. California Environmental Protection Agency. https://oehha.ca.gov/chemicals/12-dichloroethylene-cis
ChemIDplus. (2021). ChemIDplus advanced. Available online at https://chem.nlm.nih.gov/chemidplus/
Chiu WA; Micallef S; Monster AC; Bois FY. (2007). Toxicokinetics of inhaled trichloroethylene and tetrachloroethylene in humans at 1 ppm: Empirical results and comparisons with previous studies. Toxicol Sci 95: 23–36. 10.1093/toxsci/kfl129 17032701
Clark DG; Tinston DJ. (1982). Acute inhalation toxicity of some halogenated and non-halogenated hydrocarbons. Hum Exp Toxicol 1: 239–247. 10.1177/096032718200100306
Clewell HJ; Andersen ME. (1994). Physiologically-based pharmacokinetic modeling and bioactivation of xenobiotics [Review]. Toxicol Ind Health 10: 1–24. 10.1177/074823379401000101 7570610
Costa AK; Ivanetich KM. (1982). The 1,2-dichloroethylenes: their metabolism by hepatic cytochrome p-450 in vitro. Biochem Pharmacol 31: 2093–2102. 10.1016/0006-2952(82)90426-9 7115427
Costa AK; Ivanetich KM. (1984). Chlorinated ethylenes: their metabolism and effect on DNA repair in rat hepatocytes. Carcinogenesis 5: 1629–1636. 10.1093/carcin/5.12.1629 6499114
Dallas C; Gallo J; Ramanathan R; Muralidhara S; Bruckner J. (1991). Physiological pharmacokinetic modeling of inhaled trichloroethylene in rats. Toxicol Appl Pharmacol 110: 303–314. 10.1016/S0041-008X(05)80013-4 1891776
Dallas CE; Muralidhara S; Chen XM; Ramanathan R; Varkonyi P; Gallo JM; Bruckner JV. (1994). Use of a physiologically based model to predict systemic uptake and respiratory elimination of perchloroethylene. Toxicol Appl Pharmacol 128: 60–68. 10.1006/taap.1994.1180 8079355
Dallas CE; Weir FW; Feldman S; Putcha L; Bruckner JV. (1983). The uptake and disposition of 1,1-dichloroethylene in rats during inhalation exposure. Toxicol Appl Pharmacol 68: 140–151. 10.1016/0041-008X(83)90363-0 6845373
Davis AP; Grondin CJ; Johnson RJ; Sciaky D; Wiegers J; Wiegers TC; Mattingly CJ. (2021). The comparative toxicogenomics database. Davis, AP; Grondin, CJ; Johnson, RJ; Sciaky, D; Wiegers, J; Wiegers, TC; Mattingly, CJ. http://ctdbase.org/
Dorfmueller MA; Henne SP; York RG; Bornschein RL; Manson JM. (1979). Evaluation of teratogenicity and behavioral toxicity with inhalation exposure of maternal rats to trichloroethylene. Toxicology 14: 153–166. 10.1016/0300-483X(79)90061-1 538767
Dow Chemical (Dow Chemical Company). (1994). The toxicity of 1,2-dichloroethylene as determined by repeated exposures on laboratory animals, with cover letter dated 05/10/94 (sanitized) [TSCA Submission]. (OTS0557247. 86940000837S. TSCATS/442717).
Dreher EL; Beutel KK; Myers JD; Lübbe T; Krieger S; Pottenger LH. (2014). Chloroethanes and chloroethylenes. In B Elvers (Ed.), Ullmann's Encyclopedia of Industrial Chemistry (6th ed., pp. 1–81). Hoboken, NJ: Wiley‐VCH Verlag GmbH & Co. 10.1002/14356007.o06_o01.pub2
DuPont (E. I. du Pont de Nemours & Company). (1988). Teratogenicity study of trans-1,2-dichloroethylene in rats with cover letter dated 05/10/94 (sanitized) [TSCA Submission]. (OTS0557175. 86940000765S. TSCATS/442645). E. I. du Pont de Nemours and Company.
DuPont Haskell Lab (DuPont Haskell Laboratory). (1999). Initial submission: Letter from DuPont Haskell Laboratory to USEPA RE results of 4-hour inhalation median lethality study (LC50) in rats w/cis-1,2-dichloroethylene, dated 8/26/99 [TSCA Submission]. (OTS0559785. 88990000257. 8EHQ-0899–14538. TSCATS/446080). DuPont Chem.
ECHA (European Chemicals Agency). (2020). Substance infocard: cis-dichloroethylene. https://echa.europa.eu/substance-information/-/substanceinfo/100.005.328
Filser JG; Bolt HM. (1979). Pharmacokinetics of halogenated ethylenes in rats. Arch Toxicol 42: 123–136. 10.1007/BF00316492 485853
Foster AB. (1984). Deuterium isotope effects in studies of drug metabolism. Trends Pharmacol Sci 5: 524–527. 10.1016/0165-6147(84)90534-0
Franchini I; Cavatorta A; Falzoi M; Lucertini S; Mutti A. (1983). Early indicators of renal damage in workers exposed to organic solvents. Int Arch Occup Environ Health 52: 1–9. 10.1007/BF00380601 6603422
Freundt KJ; Leibaldt GP; Lieberwirth E. (1977). Toxicity studies on trans-1,2-dichloroethylene. Toxicology 7: 141–153. 10.1016/0300-483X(77)90059-2 854930
Freundt KJ; Macholz J. (1972). Cis-1,2-dichloroethylene and trans-1, 2-dichloroethylene - 2 new inhibitors of microsomal enzymes [Abstract]. Naunyn-Schmiedebergs Arch Pharmacol 274: R37.
Freundt KJ; Macholz J. (1978). Inhibition of mixed function oxidases in rat liver by trans- and cis-1,2-dichloroethylene. Toxicology 10: 131–140. 10.1016/0300-483X(78)90063-X 684758
Friberg L; Kylin B; Nystrom A. (1953). Toxicities of trichlorethylene and tetrachloroethylene and Fujiwara's pyridine-alkali reaction. Basic Clin Pharmacol Toxicol 9: 303–312.
Gargas ML; Burgess RJ; Voisard DE; Cason GH; Andersen ME. (1989). Partition coefficients of low-molecular-weight volatile chemicals in various liquids and tissues. Toxicol Appl Pharmacol 98: 87–99. 10.1016/0041-008x(89)90137-3 2929023
Gargas ML; III CH; Andersen ME. (1990). Gas uptake inhalation techniques and the rates of metabolism of chloromethanes, chloroethanes, and chloroethylenes in the rat. Inhal Toxicol 2: 295–319. 10.3109/08958379009145260
Gargas ML; Seybold PG; Andersen ME. (1988). Modeling the tissue solubilities and metabolic rate constant (Vmax) of halogenated methanes, ethanes, and ethylenes. Toxicol Lett 43: 235–256. 10.1016/0378-4274(88)90031-8 3176068
Ghantous H; Danielsson BR G; Dencker L; Gorczak J; Vesterberg O. (1986). Trichloroacetic acid accumulates in murine amniotic fluid after tri- and tetrachloroethylene inhalation. Acta Pharmacol Toxicol 58: 105–114. 10.1111/j.1600-0773.1986.tb00078.x
Hanioka N; Jinno H; Nishimura T; Ando M. (1998). Changes in hepatic cytochrome P450 enzymes by cis- and trans-1,2-dichloroethylenes in rat. Xenobiotica 28: 41–51. 10.1080/004982598239740 9493318
Haskell Laboratories. (1988). Initial submission: Teratogenicity study of trans-1,2-dichloroethylene in rats (final report) with attachments and cover letter dated 032792 [TSCA Submission]. (88–920001531. 8EHQ-0392–2889. TSCATS/422945). E. I. du Pont de Nemours and Company, Inc. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0535915.xhtml
Hehir RM; Mcnamara BP; Mclaughlin J Jr; Willigan DA; Bierbower G; Hardisty JF. (1981). Cancer induction following single and multiple exposures to a constant amount of vinyl chloride monomer. Environ Health Perspect 41: 63–72.7333245
Henck JW; Quast JF; Rampy LW. (1979). A comparison of four mouse strains exposed to subchronically inhaled vinylidene chloride (VDC). Henck, JW; Quast, JF; Rampy, LW.
Henschler D; Bonse G. (1977). Metabolic activation of chlorinated ethylenes: Dependence of mutagenic effect on electrophilic reactivity of the metabolically formed epoxides. Arch Toxicol 39: 7–12. 10.1007/BF00343270 579983
Henschler D; Bonse G. (1979). Metabolic activation of chlorinated ethylene derivatives. In Cohen Y (Ed.), Advances in Pharmacology and Therapeutics: Volume 9: Toxicology (pp. 123–130). New York, NY: Pergamon Press.
Hurtt ME; Valentine R; Alvarez L. (1993). Developmental toxicity of inhaled trans-1,2-dichloroethylene in the rat. Fundam Appl Toxicol 20: 225–230. 10.1006/faat.1993.1030 8449394
IARC (International Agency for Research on Cancer). (2021). Agents classified by the IARC monographs. Lyon, France. http://monographs.iarc.fr/ENG/Classification/List_of_Classifications.pdf
Ikeda M; Imamura T. (1973). Biological half-life of trichloroethylene and tetrachloroethylene in human subjects [Review]. Int Arch Occup Environ Health 31: 209–224. 10.1007/BF00539241
Jenkins LJ; Trabulus MJ; Murphy SD. (1972). Biochemical effects of 1,1-dichloroethylene in rats - Comparison with carbon-tetrachloride and 1,2-dichloroethylene. Toxicol Appl Pharmacol 23: 501–510. 10.1016/0041-008X(72)90052-X 4404420
JISA (Japan Industrial Safety Association). (1993). Carcinogenicity study of tetrachloroethylene by inhalation in rats and mice. Hadano, Japan. https://www.epa.gov/iris/supporting-documents-tetrachloroethylene-perchloroethylene
John JA; Smith FA; Leong BK J; Schwetz BA. (1977). The effects of maternally inhaled vinyl chloride on embryonal and fetal development in mice, rats, and rabbits. Toxicol Appl Pharmacol 39: 497–513. 10.1016/0041-008X(77)90141-7 854925
John JA; Smith FA; Schwetz BA. (1981). Vinyl chloride: inhalation teratology study in mice, rats and rabbits. Environ Health Perspect 41: 171–177. 10.2307/3429312 7333235
Johnson P; Dawson B; Goldberg S. (1998). A review: Trichloroethylene metabolites: Potential cardiac teratogens [Review]. Environ Health Perspect 106: 995–999. 10.2307/3434143 9703484
Jones BK; Hathway DE. (1978). The biological fate of vinylidene chloride in rats. Chem Biol Interact 20: 27–41. 10.1016/0009-2797(78)90078-9 630643
Karlsson JE; Rosengren LE; Kjellstrand P; Haglid KG. (1987). Effects of low-dose inhalation of three chlorinated aliphatic organic solvents on deoxyribonucleic acid in gerbil brain [Comment]. Scand J Work Environ Health 13: 453–458. 10.5271/sjweh.2015 3433047
Kelly DP. (1998). trans-1,2-Dichloroethylene: 90-day inhalation toxicity study in rats. (Laboratory Project ID HL-1998–00952). Newark, DE: E.I. du Pont de Nemours and Company, Haskell Laboratory for Toxicology and Industrial Medicine.
Kelly DP. (1999). Trans-1,2-dichloroethylene and cis-1,2-dichloroethylene: Inhalation median lethal concentration (LC50) study in rats. (Laboratory Project ID: DuPont-2806). Newark, DE: E.I. du Pont de Nemours and Company, Haskell Laboratory for Toxicology and Industrial Medicine.
Kelly DP; Hansen J; Brock W; Barter J; Burleigh-Flayer H. (2000). Acute inhalation toxicity of cis and trans isomers of 1,2-dichloroethylene in rats [Abstract]. Toxicologist 54: pg. 20.
Kjellstrand P; Holmquist B; Alm P; Kanje M; Romare S; Jonsson I; Månsson L; Bjerkemo M. (1983). Trichloroethylene: Further studies of the effects on body and organ weights and plasma butyrylcholinesterase activity in mice. Acta Pharmacol Toxicol 53: 375–384. 10.1111/j.1600-0773.1983.tb03438.x
Kjellstrand P; Holmquist B; Kanje M; Alm P; Romare S; Jonsson I; Mansson L; Bjerkemo M. (1984). Perchloroethylene: Effects on body and organ weights and plasma butyrylcholinesterase activity in mice. Acta Pharmacol Toxicol 54: 414–424. 10.1111/j.1600-0773.1984.tb01951.x
Krajewski J; Dobecki M; Gromiec J. (1980). Retention of vinyl chloride in the human lung. Occup Environ Med 37: 373–374.
Kumar P; Purohit DC; Prasad AK; al, e. (2002). Histobiochemical alterations in rat lungs induced by inhalation of trichloroethylene. J Ecophys Occup Health 2: 265–274.
Laham S. (1970). Studies on placental transfer: Trichlorethylene. Ind Med Surg 39: 46–49.
Lehmann KB; Schmidt-Kehl L. (1936). Die 13 wichtigsten Chlorkohlenwasserstoffe der Fettreihe von Standpunkt der Gewerbehygiene. Archiv fuer Hygiene und Bakteriologie 116: 131–268.
Lilly PD; Thornton-Manning JR; Gargas ML; Clewell HJ; Andersen ME. (1998). Kinetic characterization of CYP2E1 inhibition in vivo and in vitro by the chloroethylenes. Arch Toxicol 72: 609–621. 10.1007/s002040050551 9851676
Mathews JM; Etheridge AS; Raymer JH; Black SR; Pulliam DW; Bucher JR. (1998). Selective inhibition of cytochrome P450 2E1 in vivo and in vitro with trans-1,2-dichloroethylene. Chem Res Toxicol 11: 778–785. 10.1021/tx970227g 9671540
McCauley PT; Robinson M; Condie LW; Parnell M. (1990). The effects of subacute and subchronic oral exposure to cis-1,2-dichloroethylene in rats [unpublished report]. U.S. Environmental Protection Agency, U.S. Air Force.
McCauley PT; Robinson M; Daniel FB; Olson GR. (1995). The effects of subacute and subchronic oral exposure to cis-1,2-dichloroethylene in Sprague-Dawley rats. Drug Chem Toxicol 18: 171–184. 10.3109/01480549509014319 7497910
Mcdermott MJ; Mazor KA; Shost SJ; Narang RS; Aldous KM; Storm JE. (2005). Tetrachloroethylene (PCE, Perc) levels in residential dry cleaner buildings in diverse communities in New York City. Environ Health Perspect 113: 1336–1343. 10.1289/ehp.7414 16203243
Mckenna MJ; Watanabe PG; Gehring PJ. (1977). Pharmacokinetics of vinylidene chloride in the rat. Environ Health Perspect 21: 99–105. 10.1289/ehp.772199 612464
Mckenna MJ; Zempel JA; Madrid EO; Braun WH; Gehring PJ. (1978a). Metabolism and pharmacokinetic profile of vinylidene chloride in rats following oral administration. Toxicol Appl Pharmacol 45: 821–835. 10.1016/0041-008X(78)90173-4 725933
Mckenna MJ; Zemple JA; Madrid EO; Gehring PJ. (1978b). The pharmacokinetics of [14C] vinylidene chloride in rats following inhalation exposure. Toxicol Appl Pharmacol 45: 599–610. 10.1016/0041-008x(78)90121-7 705790
Mcmillan DA. (1986) Toxicity of the cis- and trans-isomers of 1,2-dichloroethylene. (Doctoral Dissertation). University of Nebraska Medical Center, Omaha, NE. Retrieved from https://dialog.proquest.com/professional/pqdtftprofmodule/docview/303446721/fulltextPDF/178313B913C6B59B493/1?accountid=102841
Mennear J; Maronpot R; Boorman G; Eustis S; Huff J; Haseman J; Mcconnell E; Ragan H; Miller R. (1986). Toxicologic and carcinogenic effects of inhaled tetrachloroethylene in rats and mice. In New concepts and developments in toxicology: Proceedings of the Fourth International Congress of toxicology held in Tokyo, Japan, July 21–25, 1986. New York: Elsevier Science Publishers.
Mertens JA. (2000). Dichloroethylene. In Ley C (Ed.), Kirk-Othmer encyclopedia of chemical technology. New York, NY: John Wiley & Sons, Inc. 10.1002/0471238961.0409030813051820.a01
Monster AC; Boersma G; Duba WC. (1976). Pharmacokinetics of trichloroethylene in volunteers, influence of workload and exposure concentration. Int Arch Occup Environ Health 38: 87–102. 10.1007/BF00378619 1002309
Monster AC; Boersma G; Duba WC. (1979a). Kinetics of trichloroethylene in repeated exposure of volunteers. Int Arch Occup Environ Health 42: 283–292. 10.1007/BF00377782 422269
Monster AC; Boersma G; Steenweg H. (1979b). Kinetics of tetrachloroethylene in volunteers; influence of exposure concentration and work load. Int Arch Occup Environ Health 42: 303–309.422271
Muller G; Spassovski M; Henschler D. (1974). Metabolism of trichloroethylene in man: II. Pharmacokinetics of metabolites. Arch Toxicol 32: 283–295. 10.1007/BF00330110 4480028
Nakahama T; Sarutani S; Inouye Y. (2000). Effects of chlorinated ethylenes on expression of rat CYP forms: Comparative study on correlation between biological activities and chemical structures. J Health Sci 46: 251–258. 10.1248/jhs.46.251
Nakajima T. (1997). Cytochrome P450 isoforms and the metabolism of volatile hydrocarbons of low relative molecular mass. J Occup Health 39: 83–91. 10.1539/joh.39.83
NIOSH (National Institute for Occupational Safety and Health). (2014). 1,2-Dichloroethylene. Immediately Dangerous to Life or Health (IDLH) concentrations. Atlanta, GA: Centers for Disease Control and Prevention, U.S. Department of Health, Education and Welfare. https://www.cdc.gov/niosh/idlh/540590.html
NIOSH (National Institute for Occupational Safety and Health). (2019). NIOSH pocket guide to chemical hazards: 1,2-Dichloroethylene. Atlanta, GA: U.S. Department of Health, Education and Welfare, Centers for Disease Control and Prevention (CDC). https://www.cdc.gov/niosh/npg/npgd0195.html
NLM (National Library of Medicine). (2021a). ChemIDplus: 1,1-Dichloroethylene. Available online at https://chem.nlm.nih.gov/chemidplus/rn/75-35-4
NLM (National Library of Medicine). (2021b). ChemIDplus: cis-1,2-Dichloroethylene. Available online at https://chem.nlm.nih.gov/chemidplus/rn/156-59-2
NLM (National Library of Medicine). (2021c). ChemIDplus: Tetrachloroethylene [USP]. Available online at https://chem.nlm.nih.gov/chemidplus/rn/127-18-4
NLM (National Library of Medicine). (2021d). ChemIDplus: trans-1,2-Dichloroethylene. Available online at https://chem.nlm.nih.gov/chemidplus/rn/156-60-5
NLM (National Library of Medicine). (2021e). ChemIDplus: Trichloroethylene [INN:NF]. Available online at https://chem.nlm.nih.gov/chemidplus/rn/79-01-6
NLM (National Library of Medicine). (2021f). ChemIDplus: Vinyl chloride. Available online at https://chem.nlm.nih.gov/chemidplus/rn/75-01-4
NLM (National Library of Medicine). (2021g). PubChem: cis-1,2-Dichloroethylene. Available online at https://pubchem.ncbi.nlm.nih.gov/compound/643833
NLM (National Library of Medicine). (2021h). PubChem: trans-1,2-Dichloroethylene. Available online at https://pubchem.ncbi.nlm.nih.gov/compound/638186
NLM (National Library of Medicine). (2021i). PubChem: Vinyl chloride. Available online at https://pubchem.ncbi.nlm.nih.gov/compound/6338
NLM (National Library of Medicine). (2021j). PubChem: Vinylidene chloride. Available online at https://pubchem.ncbi.nlm.nih.gov/compound/6366
NTP (National Toxicology Program). (1986). Toxicology and carcinogenesis studies of tetrachloroethylene (perchloroethylene) (CAS No. 127–18-4) in F344 rats and B6C3F1 mice (inhalation studies). (NTP TR 311). Research Triangle Park, NC: U.S. Department of Health and Human Services. http://ntp.niehs.nih.gov/ntp/htdocs/LT_rpts/tr311.pdf
NTP (National Toxicology Program). (2015). NTP technical report on the toxicology and carcinogenesis studies of vinylidene chloride (CAS No. 75–35-4) in F344/N rats and B6C3F1/N mice (Inhalation studies). https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr582_508.pdf. May 8, 2018
NTP (National Toxicology Program). (2016). 14th Report on carcinogens. Research Triangle Park, NC. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html
O'Brien PJ. (1988). Radical formation during the peroxidase catalyzed metabolism of carcinogens and xenobiotics: The reactivity of these radicals with GSH, DNA, and unsaturated lipid [Review]. Free Radic Biol Med 4: 169–183. 10.1016/0891-5849(88)90025-1 3281871
OECD (Organisation for Economic Co-operation and Development). (2022). The OECD QSAR toolbox [version 4.5] [Database]. Retrieved from http://www.oecd.org/chemicalsafety/risk-assessment/oecd-qsar-toolbox.htm
OSHA (Occupational Safety & Health Administration). (2020a). Air contaminants: Occupational safety and health standards for shipyard employment, subpart Z, toxic and hazardous substances. (OSHA Standard 1915.1000). Washington, DC. https://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10286
OSHA (Occupational Safety & Health Administration). (2020b). Safety and health regulations for construction: Occupational health and environmental controls: Gases, vapors, fumes, dusts, and mists: Appendix A. Available online at http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10629
OSHA (Occupational Safety & Health Administration). (2020c). Table Z-1: Limits for air contaminants. Occupational safety and health standards, subpart Z, toxic and hazardous substances. Available online at http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=9992
Parkinson A. (2001). Biotransformation of xenobiotics. In Klaassen CD (Ed.), Casarett and Doull's toxicology: The basic science of poison (6th ed., pp. 133–224). New York, NY: McGraw-Hill.
Pegg DG; Zempel JA; Braun WH; Watanabe PG. (1979). Disposition of tetrachloro(14C)ethylene following oral and inhalation exposure in rats. Toxicol Appl Pharmacol 51: 465–474. 10.1016/0041-008X(79)90371-5 538758
Pellizzari ED; Hartwell TD; Harris BS III; Waddell RD; Whitaker DA; Erickson MD. (1982). Purgeable organic compounds in mother's milk. Bull Environ Contam Toxicol 28: 322–328. 10.1007/BF01608515 7082873
Plaa GL; Larson RE. (1965). Relative nephrotoxic properties of chlorinated methane, ethane, and ethylene derivatives in mice. Toxicol Appl Pharmacol 7: 37–44. 10.1016/0041-008X(65)90072-4 14256601
Pleil JD; Lindstrom AB. (1997). Exhaled human breath measurement method for assessing exposure to halogenated volatile organic compounds. Clin Chem 43: 723–730.9166222
Pozzani UC; Weil CS; Carpenter CP. (1959). The toxicological basis of threshold limit values. 5: The experimental inhalation of vapor mixtures by rats, with notes upon the relationship between single dose inhalation and single dose oral data. Am Ind Hyg Assoc J 20: 364–369. 10.1080/00028895909343733 14434607
Quast JF; Mckenna MJ; Rampy LW; Norris JM. (1986). Chronic toxicity and oncogenicity study on inhaled vinylidene chloride in rats. Toxicol Sci 6: 105–144. 10.1016/0272-0590(86)90269-1
Rampy LW; Quast JF; Humiston CG; Balmer MF; Schwetz BA. (1977). Interim results of two-year toxicological studies in rats of vinylidene chloride incorporated in the drinking water or administered by repeated inhalation. Environ Health Perspect 21: 33–43. 10.1289/ehp.772133 612457
Sato A; Nakajima T. (1987). Pharmacokinetics of organic solvent vapors in relation to their toxicity [Review]. Scand J Work Environ Health 13: 81–93. 10.5271/sjweh.2075 3299685
Schumann AM; Quast JF; Watanabe PG. (1980). The pharmacokinetics and macromolecular interactions of perchloroethylene in mice and rats as related to oncogenicity. Toxicol Appl Pharmacol 55: 207–219. 10.1016/0041-008X(80)90082-4 7423514
Schwetz BA; Leong BK J; Gehring PJ. (1975). The effect of maternally inhaled trichloroethylene, perchloroethylene, methyl chloroform, and methylene chloride on embryonal and fetal development in mice and rats. Toxicol Appl Pharmacol 32: 84–96. 10.1016/0041-008X(75)90197-0 1135881
Sharma RP; Gehring PJ. (1979). Immunologic effects of vinyl chloride in mice. Ann N Y Acad Sci 320: 551–563.287402
Short RD Jr; Minor JL; Winston JM; Ferguson B; Unger T; Lee CC. (1977a). Toxicity studies of selected chemicals Task II: the developmental toxicity of vinylidene chloride inhaled by rats and mice during gestation. Short, RD, Jr; Minor, RD; Winston, JM; Ferguson, B; Unger, T; Lee, CC.
Short RD; Winston JM; Minor JL; Hong CB; Seifter J; Lee CC. (1977b). Toxicity of vinylidene chloride in mice and rats and its alteration by various treatments. J Toxicol Environ Health 3: 913–921. 10.1080/15287397709529625 202722
Short RD; Winston JM; Minor JL; Seifter J; Lee CC. (1977c). Effect of various treatments on toxicity of inhaled vinylidene chloride. Environ Health Perspect 21: 125–129. 10.1289/ehp.7721125 612437
Siegel J; Jones RA; Coon RA; Lyon JP. (1971). Effects on experimental animals of acute, repeated and continuous inhalation exposures to dichloroacetylene mixtures. Toxicol Appl Pharmacol 18: 168–174. 10.1016/0041-008X(71)90326-7 5542822
Simmonds AC; Reilly CA; Baldwin RM; Ghanayem BI; Lanza DL; Yost GS; Collins KS; Forkert PG. (2004). Bioactivation of 1,1-dichloroethylene to its epoxide by CYP2E1 and CYP2F enzymes. Drug Metab Dispos 32: 1032–1039.15319346
Storm JE; Mazor KA; Aldous KM; Blount BC; Brodie SE; Serle JB. (2011). Visual contrast sensitivity in children exposed to tetrachloroethylene. Arch Environ Occup Health 66: 166–177. 10.1080/19338244.2010.539638 21864105
Suzuki Y. (1978). Pulmonary tumors induced in mice by vinyl chloride monomer. Environ Res 16: 285–301.679916
Suzuki Y. (1981). Neoplastic and nonneoplastic effects of vinyl chloride in mouse lung. Environ Health Perspect 41: 31–52. 10.1289/ehp.814131 7333244
Thornton SR; Schroeder RE; Robison RL; Rodwell DE; Penney DA; Nitschke KD; Sherman WK. (2002). Embryo-fetal developmental and reproductive toxicology of vinyl chloride in rats. Toxicol Sci 68: 207–219. 10.1093/toxsci/68.1.207 12075123
U.S. EPA (U.S. Environmental Protection Agency). (1988). Recommendations for and documentation of biological values for use in risk assessment [EPA Report]. (EPA600687008). Cincinnati, OH. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=34855
U.S. EPA (U.S. Environmental Protection Agency). (1994). Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry [EPA Report]. (EPA600890066F). Research Triangle Park, NC. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=71993&CFID=51174829&CFTO KEN=25006317
U.S. EPA (U.S. Environmental Protection Agency). (2000). Toxicological review of vinyl chloride [EPA Report]. (EPA635R00004). Washington, DC. http://www.epa.gov/iris/toxreviews/1001tr.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2002a). A review of the reference dose and reference concentration processes. (EPA630P02002F). Washington, DC. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2002b). Toxicological review of 1,1-dichloroethylene (CAS No. 75–35-4) [EPA Report]. (EPA635R02002). https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0039tr.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2003). Toxicological review of dichloroacetic acid (CAS No. 79–43-6) [EPA Report]. (EPA635R03007). Washington, DC. http://www.epa.gov/iris/toxreviews/0654tr.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2005). Guidelines for carcinogen risk assessment [EPA Report]. (EPA630P03001F). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3–25-05.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2008). 1,2-Dichloroethene (CAS reg. no. 540–59-0), cis-1,2-dichloroethene (CAS reg. no. 156–59-2), trans-1,2-dichloroethene (CAS reg. no. 156–60-5): Acute exposure guideline levels (AEGLs), final. Washington, DC: National Advisory Committee for Acute Exposure Guideline Levels. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2014-11/documents/1_1_and_1_2_dichloroethylene.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2010). Toxicological review of cis-1,2-dichloroethylene and trans-1,2-dichloroethylene (CAS nos. cis: 156–592-2: trans- 156–60-5: mixture: 540–59-0). In support of summary information on the Integrated Risk Information System (IRIS) [EPA Report]. (EPA635R09006F). Washington, DC. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0418tr.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2011a). Chemical assessment clustering engine (ChemACE). Retrieved from https://www.epa.gov/tsca-screening-tools/chemical-assessment-clustering-engine-chemace
U.S. EPA (U.S. Environmental Protection Agency). (2011b). Health effects assessment summary tables (HEAST) for superfund [EPA Report]. Washington, DC. https://epa-heast.ornl.gov/heast.php
U.S. EPA (U.S. Environmental Protection Agency). (2011c). Provisional peer-reviewed toxicity values for cis-1,2-Dichloroethylene (CASRN 156–59-2) [EPA Report]. Cincinnati, OH. http://hhpprtv.ornl.gov/issue_papers/Dichloroethylene12cis.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2011d). Toxicological review of trichloroethylene (CAS No. 79–01-6) in support of summary Information on the Integrated Risk Information System (IRIS) [EPA Report]. (EPA635R09011F). Washington, DC. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100CB6V.txt
U.S. EPA (U.S. Environmental Protection Agency). (2012). Toxicological review of tetrachloroethylene (Perchloroethylene) (CASRN 127–18-4) in support of summary information on the Integrated Risk Information System (IRIS) [EPA Report]. (EPA635R08011F). Washington, DC: National Center for Environmental Assessment. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0106tr.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2018a). 2018 Edition of the drinking water standards and health advisories tables [EPA Report]. (EPA822F18001). Washington, DC: U.S. Environmental Protection Agency, Office of Water. https://www.epa.gov/system/files/documents/2022-01/dwtable2018.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2018b). Compiled AEGLs (Acute Exposure Guideline Levels) values. Washington, DC: US Environmental Protection Agency. https://www.epa.gov/aegl/compiled-acute-exposure-guideline-values-aegls
U.S. EPA (U.S. Environmental Protection Agency). (2019). CompTox Chemicals Dashboard [Database]. Research Triangle Park, NC. Retrieved from https://comptox.epa.gov/dashboard
U.S. EPA (U.S. Environmental Protection Agency). (2020). Provisional peer-reviewed toxicity values for trans-1,2-dichloroethylene (CASRN 156–60-5). (EPA/690/R-20/006F). Washington, DC: Center for Public Health and Environmental Assessment, U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/pprtv/recordisplay.cfm?deid=349934
U.S. EPA (U.S. Environmental Protection Agency). (2021a). CompTox chemicals dashboard: 1,1-Dichloroethylene. Available online at https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID8021438
U.S. EPA (U.S. Environmental Protection Agency). (2021b). CompTox chemicals dashboard: Vinyl chloride. Available online at https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID8021434
U.S. EPA (U.S. Environmental Protection Agency). (2021c). TSCA chemical substance inventory. Download the non-confidential TSCA inventory. Available online at https://www.epa.gov/tsca-inventory/how-access-tsca-inventory
Ungváry G; Hudák A; Tátrai E; Lörincz M; Folly G. (1978). Effects of vinyl chloride exposure alone and in combination with trypan blue--applied systematically during all thirds of pregnancy on the fetuses of CFY rats. Toxicology 11: 45–54.705803
Völkel W; Friedewald M; Lederer E; Pähler A; Parker J; Dekant W. (1998). Biotransformation of perchloroethene: Dose-dependent excretion of trichloroacetic acid, dichloroacetic acid, and N-acetyl-S-(trichlorovinyl)-L-cysteine in rats and humans after inhalation. Toxicol Appl Pharmacol 153: 20–27. 10.1006/taap.1998.8548 9875296
von Oettingen WF. (1937). The halogenated hydrocarbons: Their toxicity and potential dangers. J Ind Hyg Toxicol 19: 349–448.
von Oettingen WF. (1955). The halogenated aliphatic, olefinic, cyclic, aromatic, and aliphatic-aromatic hydrocarbons including the halogenated insecticides, their toxicity and potential dangers. In Public Health Service publication, no 414. (Public Health Service Publication 414). Washington, DC: U.S. Department of Health, Education, and Welfare, Public Health Service.
Wang NC; Zhao QJ; Wesselkamper SC; Lambert JC; Petersen D; Hess-Wilson JK. (2012). Application of computational toxicological approaches in human health risk assessment. I. A tiered surrogate approach. Regul Toxicol Pharmacol 63: 10–19. 10.1016/j.yrtph.2012.02.006 22369873
Watanabe PG; Mcgowan GR; Madrid EO; Gehring PJ. (1976). Fate of [14C]vinyl chloride following inhalation exposure in rats. Toxicol Appl Pharmacol 37: 49–59. 10.1016/s0041-008x(76)80007-5 968906
Withey JR. (1976). Pharmacodynamics and uptake of vinyl chloride monomer administered by various routes to rats. J Toxicol Environ Health 1: 381–394. 10.1080/15287397609529338 1246084
Yamano T; Morita S. (1992). Hepatotoxicity of trichlorfon and dichlorvos in isolated rat hepatocytes. Toxicology 76: 69–77.1475794