# APPENDIX A SCREENING NONCANCER PROVISIONAL VALUES

Due to the lack of evidence described in the main Provisional Peer-Reviewed Toxicity Value (PPRTV) document, it is inappropriate to derive provisional inhalation toxicity values for cis-1,2-dichloroethylene (cis-1,2-DCE). However, some information is available for this chemical, which although insufficient to support deriving a provisional toxicity value under current guidelines, may be of use to risk assessors. In such cases, the Center for Public Health and Environmental Assessment (CPHEA) summarizes available information in an appendix and develops a “screening value.” Appendices receive the same level of internal and external scientific peer review as the provisional reference values to ensure their appropriateness within the limitations detailed in the document. Users of screening toxicity values in an appendix to a PPRTV assessment should understand that there could be more uncertainty associated with the derivation of an appendix screening toxicity value than for a value presented in the body of the assessment. Questions or concerns about the appropriate use of screening values should be directed to the CPHEA.

## APPLICATION OF AN ALTERNATIVE ANALOGUE APPROACH (METHODS)

The analogue approach allows for the use of data from related compounds to calculate screening values when data for the compound of interest are limited or unavailable. Details regarding searches and methods for analogue analysis are presented in Wang et al. (2012). Three types of potential analogues (structural, metabolic, and toxicity-like) are identified to facilitate the final analogue chemical selection. The analogue approach may or may not be route-specific or applicable to multiple routes of exposure. All information was considered together as part of the final weight-of-evidence (WOE) approach to select the most suitable analogue both toxicologically and chemically.

The analogue identification approach of Wang et al. (2012) was expanded to collect a more comprehensive set of candidate analogues for the compounds undergoing a U.S. Environmental Protection Agency (U.S. EPA) PPRTV screening-level assessment. As described below, this method includes application of a variety of tools and methods for identifying candidate analogues that are similar to the target chemical based on chemical structure and key features; metabolic relationships; or related toxic effects and mechanisms of action.

To identify structurally related compounds, an initial pool of analogues is identified using automated tools, including ChemIDplus (ChemIDplus, 2021), CompTox Chemicals Dashboard (U.S. EPA, 2019), and Organisation for Economic Co-operation and Development (OECD) Quantitative Structure-Activity Relationship (QSAR) Toolbox (OECD, 2022). Additional analogues identified as ChemIDplus-related substances, parent, salts, and mixtures, and Comptox-related substances are considered. Comptox GenRA analogues are collected when available using the methods available on the publicly available GenRA Beta version, which may include Morgan fingerprints, Torsion fingerprints, ToxPrints and ToxCast, Tox21, and ToxRef data. For compounds that have very few analogues identified by structural similarity using a similarity threshold of 0.8 or 80%, substructure searches in the QSAR Toolbox may be performed, or similarity searches may be rerun using a reduced similarity threshold (e.g., 70 or 60%). The compiled list of candidate analogues is batch run through the CompTox Chemicals Dashboard where QSAR-ready simplified molecular-input line-entry system (SMILES) are collected and toxicity data availability are determined (e.g., from the Agency for Toxic Substances and Disease Registry [ATSDR], Office of Environmental Health Hazard Assessment [OEHHA), California Environmental Protection Agency [CalEPA], U.S. EPA Integrated Risk Information System [IRIS], PPRTVs). The batch output information is then uploaded into the Chemical Assessment Clustering Engine (ChemACE) (U.S. EPA, 2011a), which clusters the chemicals based on chemical fragments and displays the toxicity data availability for each candidate. The ChemACE output is reviewed by an experienced chemist, who narrows the list of structural analogues based on known or expected structure-toxicity relationships, reactivity, and known or expected metabolic pathways.

Toxicokinetic studies identified from the literature searches performed for this PPRTV assessment were used to identify metabolic analogues (metabolites and metabolic precursors). Metabolites were also identified from the two OECD QSAR Toolbox metabolism simulators (in vivo rat metabolism simulator and rat liver S9 metabolism simulator). Targeted PubMed searches were conducted to identify metabolic precursors and other compounds that share any of the observed or predicted metabolites identified for the target chemical. Metabolic analogues are then added to the pool of candidate analogues and toxicity data availability is determined (e.g., from ATSDR, OEHHA, CalEPA, U.S. EPA IRIS, PPRTVs).

In vivo toxicity data for the target chemical (if available from the literature searches) are evaluated to determine whether specific or characteristic toxicity was observed (e.g., cholinesterase inhibition, inhibition of oxidative phosphorylation). In addition, in vitro mechanistic data identified from the literature searches or obtained from tools including GenRA, ToxCast/Tox21, and Comparative Toxicogenomics Database (CTD) (Davis et al., 2021) were evaluated for this purpose. Data from CompTox Chemicals Dashboard ToxCast/Tox21 are collected to determine bioactivity of the target chemical in in vitro assays that may indicate potential mechanism(s) of action. The GenRA option within the Dashboard also offers an option to search for analogues based on similarities in activity in ToxCast/Tox21 in vitro assays. Using the ToxCast/Tox21 bioactivity data, nearest neighbors identified with similarity indices of ≥0.5 may be considered potential candidate analogues. The CTD (Davis et al., 2021) is searched to identify compounds with gene interactions similar to interactions induced by the target chemical; compounds with gene interactions similar to the target chemical (with a similarity index >0.5) may be considered potential candidate analogues. These compounds are then added to the pool of candidate analogues, and toxicity data availability is determined (e.g., from ATSDR, OEHHA, CalEPA, U.S. EPA IRIS, PPRTVs).

The tools used for the expanded analogue searches were selected because they are publicly available, which allows for transparency and reproducibility of the results, and because they are supported by U.S. and OECD agencies, updated regularly, and widely used. The application of a variety of different tools and methods to identify candidate analogues serves to minimize the limitations of any individual tool with respect to the pool of chemicals included, chemical fragments considered, and methods for assessing similarity. Further, the inclusion of techniques to identify analogues based on metabolism and toxicity or bioactivity expands the pool of candidates beyond those based exclusively on structural similarity.

## ANALOGUE SEARCH PROCESS

The initial analogue search focused on the identification of chemicals structurally similar to cis-1,2-DCE using the U.S. EPA CompTox Chemicals Dashboard (Tanimoto method) [successor to the DSSTox, one of the tools discussed in Wang et al. (2012)], ChemID Plus (method not described) [also discussed in Wang et al. (2012)], and the more recently developed OECD Toolbox (Dice method). The GenRA module (Beta version) in the Dashboard was employed to identify structural analogues but was not functional for this compound (returned an error message due to insufficient data availability). Results of the search are presented in Table A-1. Eight unique structural analogues were identified, based on a similarity threshold criterion of 80%. One identified analogue (vinyl chloride-d3, CASRN 6745-35-3) was excluded because it is a deuterated compound (replacing a chemical’s nondeuterated hydrogens (i.e., protium or hydrogen-1) with deuterium can alter the chemical’s toxicokinetics) (Foster, 1984).

Table A-1 Candidate Structural Analogues Identified for cis-1,2-DCE

Tool (method) | Similarity Threshold | Number of Analogues Identified | Analogue (CASRN) Selected for Toxicity Value Searches^b^
Dashboard (Tanimoto) | 80% | 4^a^ | - trans-1,2-DCE (156-60-5); - 1,2-DCE, mixed isomers (540-59-0); - Vinyl chloride (75-01-4)
OECD Toolbox (Dice) | 80% | 3 | - trans-1,2-DCE (156-60-5); - 1,2-DCE, mixed isomers (540-59-0); - (1E,3Z)-1,4-Dichlorobuta-1,3-diene (3588-13-4)
ChemID Plus (method not described) | 80% | 5 | - trans-1,2-DCE (156-60-5); - 1,2-DCE, mixed isomers (540-59-0); - (Z)-1-Chloro-2-fluoroethene (2268-31-7); - (E)-1-Chloro-2-fluoroethene (2268-32-8); - 1-Chloro-2-fluoroethene, mixed isomers (460-16-2)

a One of the four was not selected for toxicity value searches because it is a deuterated compound (see text).

b Bold shows compounds with inhalation toxicity values.

cis-1,2-DCE = cis-1,2-dichloroethylene; OECD = Organisation for Economic Cooperation and Development; trans-1,2-DCE = trans-1,2-dichloroethylene.

The seven identified candidate structural analogues for cis-1,2-DCE were searched for inhalation toxicity values. Of these, inhalation toxicity values were located only for trans-1,2-dichloroethylene (trans-1,2-DCE; CASRN 156-60-5) and vinyl chloride (CASRN 75-01-4).

Metabolites, metabolic precursors, and compounds that share metabolites with cis-1,2-DCE were also considered for analogues. As discussed in Section 2.1.3 in the main document, the primary liver metabolites of cis-1,2-DCE (based on in vitro studies using rat liver microsomes) are dichloroacetaldehyde (CASRN 79-02-7), 2,2-dichloroethanol (CASRN 598-38-9), and 2,2-dichloroacetic acid (DCA; CASRN 79-43-6) (Bonse et al., 1975). No information on metabolism in vivo was located, nor were data on metabolism in tissues other than the liver. As hepatic metabolites have been identified and could be relevant to inhalation exposure, they were considered candidate analogues. No inhalation toxicity values were identified, however, for dichloroacetaldehyde, 2,2-dichloroethanol, or DCA.

PubMed searches (searching “cis-1,2-dichloroethylene” or “156-59-2” and “metabolite”) were conducted to identify metabolic precursors to cis-1,2-DCE. No metabolic precursors yielding cis-1,2-DCE in vivo or in vitro were identified by this method. PubMed was also searched to identify other compounds that are metabolized to dichloroacetaldehyde, 2,2-dichloroethanol, or DCA (searching the metabolite name or CASRN and “metabolite”). The search identified four other compounds reportedly metabolized to one of the three cis-1,2-DCE metabolites: 1,1-dichloroethylene (1,1-DCE; CASRN 75-35-4) (Simmonds et al., 2004); trichloroethylene (TCE; CASRN 79-01-6) (Johnson et al., 1998); and the organophosphate pesticides, trichlorphon and dichlorvos (Yamano and Morita, 1992). The organophosphate pesticides were not considered further as candidate analogues on the basis of unshared structural properties with the target chemical (i.e., cis-1,2-DCE is not an organophosphate.) In the toxicological review for cis- and trans-1,2-DCE, U.S. EPA (2010) reported that trans-1,2-DCE is metabolized to the same compounds as is cis-1,2-DCE; thus, it can be considered a potentially relevant analogue on this basis, in addition to the structural similarity described above. Review of the metabolism information in the U.S. EPA (2011d) toxicological review for TCE also showed that DCA, a known metabolite of cis-1,2-DCE, can also be formed during metabolism of three other compounds: tetrachloroethylene (Perc; CASRN 127-18-7); 1,1-dichloroethane (CASRN 75-34-3); and 1,1,1,2-tetrachloroethane (CASRN 630-20-6). Among the six nonorganophosphate compounds sharing metabolites with cis-1,2-DCE, four chemicals (i.e., trans-1,2-DCE, Perc, 1,1-DCE, and TCE) have subchronic and/or chronic inhalation toxicity values and were selected as candidate metabolic analogues. No inhalation toxicity values were identified for 1,1-dichloroethane or 1,1,1,2-tetrachloroethane. Table A-2 summarizes the candidate metabolic analogues for 1,2-DCE.

Table A-2 Candidate Metabolic Analogues of cis-1,2-DCE

Relationship to cis-1,2-DCE | Compound^a^ | CASRN
Metabolic precursor | None identified
Metabolite | Dichloroacetaldehyde | 79-02-7
Metabolite | Dichloroacetic acid | 79-43-6
Metabolite | 2,2-Dichloroethanol | 598-38-9
Shares common metabolite(s) | 1,1-Dichloroethane | 75-34-3
Shares common metabolite(s) | 1,1-Dichloroethylene | 75-35-4
Shares common metabolite(s) | trans-1,2-Dichloroethylene | 156-60-5
Shares common metabolite(s) | Trichloroethylene | 79-01-6
Shares common metabolite(s) | 1,1,1,2-Tetrachloroethane | 630-20-6
Shares common metabolite(s) | Tetrachloroethylene | 127-18-4

a Bold shows compounds with inhalation toxicity values.

cis-1,2-DCE = cis-1,2-dichloroethylene.

In addition to structural and metabolic data, available toxicity and mechanistic data for cis-1,2-DCE were evaluated to identify candidate analogues. The GenRA option within the Dashboard offers an option to search for analogues on the basis of similarities in activity in in vitro assays in ToxCast/Tox21; however, for cis-1,2-DCE, the GenRA module returned an error message. cis-1,2-DCE was only active in one ToxCast/Tox21 assay (of 235) and was not active in any EDSP21 assays (n = 22) or PubChem assays (n = 421). The single assay in which this compound was active was TOX21_RT_HEK293_FLO_16hr_viability. The endpoint of this assay (cell viability in human embryonic kidney cells) cannot be used to infer specific mechanisms of toxicity. The CTD had no entry for cis-1,2-DCE.

The toxicological data for cis-1,2-DCE, described in Section 2 of the main document, do not suggest any specific, characteristic toxicity that could be used to identify candidate analogues. Repeat-dose gavage studies identified the liver and kidneys as target organs (McCauley et al., 1995; McCauley et al., 1990). The target organs of the oral study might or might not be relevant to inhalation. The only inhalation study available, an unpublished acute lethality study (DuPont Haskell Lab, 1999), reported weight loss and clinical signs of central nervous system (CNS) depression (unresponsiveness, weakness, irregular respiration) at lethal concentrations but did not evaluate liver or kidney effects. None of the effects identified in the limited in vivo studies of cis-1,2-DCE suggested a characteristic or unique mechanism of toxicity that could be used to inform candidate analogue selection.

In summary, searches for structural, metabolic, and toxicity/mechanistic analogues for cis-1,2-DCE yielded a total of 15 unique analogues: 7 structural analogues (excluding 1 deuterated compound) and 9 metabolism-related analogues (excluding 2 organophosphates), 1 of which is also a structural analogue (trans-1,2-DCE). No analogues were identified on the basis of having similar mechanisms or modes-of-action (MOAs). Of the 15 identified candidates, 5 were found to have inhalation toxicity values: 1 structural analogue (vinyl chloride); 3 chemicals (1,1-DCE, Perc, and TCE) that share at least one common metabolite with the target compound; and trans-1,2-DCE, which is both a structural analogue and shares common metabolites with the target chemical.

### Structural/Physicochemical Properties Similarity Comparisons

Table A-3 summarizes the physicochemical properties of the analogues. cis-1,2-DCE and the candidate analogues are members of the volatile organic compounds (VOC) chemical class. cis-1,2-DCE, trans-1,2-DCE, and 1,1-DCE share the same molecular weight. Melting and boiling points show that all of the compounds are liquids at room temperature except for vinyl chloride, which is a gas. Based on the Henry’s law constants and vapor pressures, all of the compounds are expected to volatilize from water to air and from soil to air, respectively, and will exist mostly in the vapor (gas) phase in the atmosphere. cis-1,2-DCE and the candidate analogues are soluble in water. Vinyl chloride, with one chlorine atom, is the most water-soluble and has the lowest molecular weight and log K_ow_ value of the group. Perc, with four chlorine atoms, is the least water-soluble and has the highest molecular weight and log K_ow_ value. The target compound and all candidate analogues are expected to be bioavailable by the oral and inhalation routes (based on vapor pressure, water solubility, and log K_ow_ values). Overall, trans-1,2-DCE is the most similar candidate analogue to cis-1,2-DCE based on structural and physicochemical properties.

Table A-3 Physicochemical Properties of cis-1,2-DCE (CASRN 156-59-2) and Candidate Analogues^a^

Chemical | cis-1,2-DCE | trans-1,2-DCE | 1,1-DCE | Perc | TCE | Vinyl Chloride
Role | Target | Analogue | Analogue | Analogue | Analogue | Analogue
Structure | Physochemical Properties of cis-1,2-DCE and Candidate Analogues Chemical Structure for cis-1,2-DCE | Physochemical Properties of cis-1,2-DCE and Candidate Analogues Analogue Chemical Structure for trans-1,2-DCE | Physochemical Properties of cis-1,2-DCE and Candidate Analogues Analogue Chemical Structure for 1,1-DCE | Physochemical Properties of cis-1,2-DCE and Candidate Analogues Analogue Chemical Structure for Perc | Physochemical Properties of cis-1,2-DCE and Candidate Analogues Analogue Chemical Structure for TCE | Physochemical Properties of cis-1,2-DCE and Candidate Analogues Analogue Chemical Structure for Vinyl Chloride
CASRN | 156-59-2 | 156-60-5 | 75-35-4 | 127-18-4 | 79-01-6 | 75-01-4
DTXSID | 2024030 | 7024031 | 8021438 | 2021319 | 0021383 | 8021434
Molecular weight (g/mol) | 96.94 | 96.94 | 96.94 | 165.82 | 131.38 | 62.5
Melting point (°C) | −64.9 | −59.7 | −122 | −11.6 | −83.5 | −155
Boiling point (°C) | 54.4 | 52.0 | 32.5 | 121 | 87.0 | −13.7
Vapor pressure (mm Hg) | 200^b^ | 331^b^ | 600 | 18.5 | 69.0 | 2,980
Henry’s law constant (atm-m^3^/mole at 25°C) | 0.00673 | 0.00673 | 0.0261 | 0.0177 | 0.00985 | 0.0278
Water solubility (mol/L) | 0.0493 | 0.0484 | 0.0235 | 0.00178 | 0.0100 | 0.0923
Octanol-water partition coefficient (log K_ow_) | 1.86 | 1.86 | 2.13 | 3.40 | 2.51 | 1.46^b^

a Data were extracted from the U.S. EPA CompTox Chemicals Dashboard: cis-1,2-dichloroethylene, CASRN 156-59-2; https://comptox.epa.gov/dashboard/chemical/properties/DTXSID2024030; accessed May 12, 2021; trans-1,2-dichloroethylene, CASRN 156-60-5; https://comptox.epa.gov/dashboard/chemical/properties/DTXSID7024031; accessed May 12, 2021; 1,1-dichloroethylene (1,1-DCE), CASRN 75-35-4; https://comptox.epa.gov/dashboard/chemical/properties/DTXSID8021438; accessed May 12, 2021; tetrachloroethylene (Perc), CASRN 127-18-4; https://comptox.epa.gov/dashboard/chemical/properties/DTXSID2021319; accessed May 12, 2021; trichloroethylene (TCE), CASRN 79-01-6; https://comptox.epa.gov/dashboard/chemical/properties/DTXSID0021383; accessed May 12, 2021; vinyl chloride, CASRN 75-01-4; https://comptox.epa.gov/dashboard/chemical/properties/DTXSID8021434; accessed May 12, 2021; all presented values are experimental averages unless otherwise specified.

b Compound-specific PubChem records (NLM, 2021g, h, i, j).

cis-1,2-DCE = cis-1,2-dichloroethylene; DCE = 1,1-dichloroethylene; DTXSID = DSSTox substance identifier; Perc = tetrachloroethylene; TCE = trichloroethylene; trans-1,2-DCE = trans-1,2-dichloroethylene; U.S. EPA = U.S. Environmental Protection Agency.

Structural alerts and toxicity predictions were identified using computational tools from the OECD QSAR Toolbox profilers, ToxAlerts, Toxtree, and Patty’s Toxicology, 6th Edition (Bingham and Cohrssen, 2012). The model results for cis-1,2-DCE and its analogue compounds are shown in Figure A-1. Concerns for protein binding, hepatotoxicity, developmental or reproductive toxicity, and reactivity or metabolism of cis-1,2-DCE and its analogues were flagged when indicated by models within each predictive tool. Notably, cis-1,2-DCE and trans-1,2-DCE share the same structure activity relationship (SAR) predictions across all domains evaluated.

Figure A-1 Structural Alerts for cis-1,2-DCE and Candidate Analogues

cis-1,2-DCE and all candidate analogues, except for 1,1-DCE, met criteria indicating potential for protein binding by at least one model. The OECD QSAR Toolbox SN_2_ and SN Vinyl at vinylic (sp2) carbon atom alerts are for protein binding through an SN_2_ type mechanism with a halogen as a leaving group; however, these alerts have no chemicals reported in their training set to compare with cis-1,2-DCE and the candidate analogues.

The OECD QSAR Toolbox Hazard Evaluation Support System (HESS) model indicated a concern for hepatotoxicity for cis-1,2-DCE and all analogues. The structural alert applies to halogenated aliphatic compounds that do not contain a ring. The OECD QSAR Toolbox HESS model alert is based on data from 20 halogenated aliphatics, including the candidate analogue trans-1,2-DCE (CASRN 156-60-5). Chlorinated aliphatic compounds cause in vivo liver necrosis by multiple mechanistic pathways, including oxidative metabolism and reductive dehalogenation (Parkinson, 2001; O'Brien, 1988; Anders, 1985).

The OECD QSAR Toolbox Developmental and Reproductive Toxicity (DART) model indicated a concern for developmental and/or reproductive toxicity for cis-1,2-DCE and all analogues based on the structural alert for small (C1−4), halo- and multihalo-alkenes. The alert is derived from data on three chemicals: vinyl chloride (CASRN 75-01-4), hexachloro-1,3-butadiene (CASRN 87-68-3), and 2-chloro-1,3-butadiene (CASRN 126-99-8).

The ToxAlerts tool showed potential for reactivity and/or metabolism for cis-1,2-DCE and all analogues based on at least one of four reported structural alerts: the presence of an alkyl halide, haloethylene, acyclic gem-dihalosubstituted carbon atom, or polyhalogenated compound containing at least four halogen (chlorine, bromine, iodine) atoms. Supporting documentation for interpretation of these ToxAlerts is limited.

### Toxicokinetic Similarity Comparisons

Table A-4 summarizes available toxicokinetic data for cis-1,2-DCE and the structurally similar compounds identified as potential analogues. cis-1,2-DCE and the candidate analogues are rapidly and readily absorbed via inhalation, with the rate and extent of absorption influenced by the concentration and duration of exposure, ventilation rates, cardiac output, body mass, physical activity, and blood-air partition coefficients. Available data indicate that the inhalation uptake of cis-1,2-DCE is ∼2 times greater than that of the trans isomer (U.S. EPA, 2020, 2010; ATSDR, 1996).

Table A-4 ADME Data for cis-1,2-DCE (CASRN 156-59-2) and Candidate Analogues^a^

Chemical; CASRN | cis-1,2-DCE; 156-59-2 | trans-1,2-DCE; 156-60-5 | 1,1-DCE; 75-35-4 | Perc; 127-18-4 | TCE; 79-01-6 | Vinyl Chloride; 75-01-4
Structure | Chemical Structure for cis-1,2-DCE | Analogue Chemical Structure for trans-1,2-DCE | Analogue Chemical Structure for 1,-1-DCE | Analogue Chemical Structure for Perc | Analogue Chemical Structure for TCE | Analogue Chemical Structure for Vinyl Chloride
Role | Target | Analogue | Analogue | Analogue | Analogue | Analogue
DTXSID | 2024030 | 7024031 | 8021438 | 2021319 | 0021383 | 8021434
Absorption
Rate and extent of inhalation absorption | Humans: ND; Laboratory animals:; [underlined: Rats exposed to vapor in a closed chamber (single dose of 79–39,652 mg/m^3^)]; - Rapid uptake from air with equilibrium achieved at ~2 h.; - Inhalation uptake ~2 times that of the trans isomer (at equilibrium, the ratio of uptake to exhalation was 20 for cis vs. 11.5 for trans, and this is consistent with the partition coefficients shown below). | Humans:; [underlined: Human subjects (n = 2) exposed to either vapor or aerosol (3,291 and 8,803 mg/m^3^ for 30 min)]; - 72–75% of inhaled amount is absorbed via lungs.; Laboratory animals:; [underlined: Rats exposed to vapor in a closed chamber (single dose of 79–39,652 mg/m^3^)]; - Rapid uptake from air with equilibrium achieved at ~1.5 h.; - Inhalation uptake ~1/2 that for cis isomer (at equilibrium, the ratio of uptake to exhalation was 20 for cis vs. 11.5 for trans, and this is consistent with the partition coefficients shown below). | Humans: ND; Laboratory animals:; [underlined: Rats exposed to vapor (100, 300, 600, or 1,200 mg/m^3^ for 3 h)]; - Rapid uptake from air with substantial levels in venous blood within 2 min and equilibrium blood levels achieved within 45 min (similar pattern at 1,200 mg/m^3^, although blood levels continued slowly increasing through exposure so that equilibrium was never achieved).; - At equilibrium during the last 90 min of 3-h exposure, systemic uptake was 72–77% at 100–600 mg/m^3^ (uptake decreased from ~60% to ~50% over the same time period at 1,200 mg/m^3^). | Humans:; [underlined: Human subjects (n = 7) exposed to vapor in an open chamber (6.8 mg/m^3^ for 6 h)]; - 64–100% of inhaled amount is absorbed via lungs.; - Peak levels in blood occurred near the end of the 6-h period.; Laboratory animals:; [underlined: Rats exposed via nose- only inhalation (340 or 3,400 mg/m^3^ for 2 h)]; - Rapid uptake from air with substantial levels in arterial blood within 2 min; blood levels increased throughout 2 h exposure, with the rate of increase higher at the higher exposure level. | Humans:; [underlined: Human subjects exposed to vapor (376–1,080 mg/m^3^ for 30 min–5 h)]; - 37–64% of inhaled amount is absorbed via lungs.; [underlined: Human subjects (n = 5) exposed via inhalation in a chamber (537 mg/m^3^ for 6 h)]; - Peak levels in blood occurred after 1–2 h.; Laboratory animals:; [underlined: Rats exposed to vapor (273–2,730 mg/m^3^ for 2 h)]; - Rapid uptake from air with substantial levels in blood within 5 min and equilibrium blood levels achieved within 30 min.; - After the first 20 min of exposure, when near- steady-state levels in exhaled breath were reached, systemic uptake was relatively constant at ~50% at 340 mg/m^3^ and ~40% at 3,400 mg/m^3^. | Humans:; [underlined: Human subjects exposed to vapor by gas mask (7.5–60 mg/m^3^ for 6 h)]; - Retention (difference between inhaled and exhaled air) averaged 42%, with maximum values reached within 15 min.; - At equilibrium during the last 60 min of 2-h exposure, systemic uptake was 69–71%.; Laboratory animals:; [underlined: Rats exposed to vapor (2,600–18,200 mg/m^3^ for 5 h)]; - Equilibrium blood levels achieved within 30 min.; [underlined: Rats exposed to vapor in a closed system (260 mg/m^3^ for 1 h]); - ~40% of inhaled [^14^C] absorbed via the lungs.
Human blood-gas partition coefficient | 9.2–9.85 | 5.8–6.08 | ND | 10.3–19.8 | 8.1–11.7 | 1.16
Rodent blood-gas partition coefficient | 21.6 | 9.58 | 5 | 18.9–33.5 | 13.3–25.82 | 1.6–2.8
Distribution
Extent of distribution | Humans and laboratory animals: ND; [underlined: Rat tissue homogenates exposed to vapor (793–1,586 mg/m^3^ for 1–4 h)]; - The tissue:air partition coefficients determined for rats in vitro were 227 (fat), 15.3 (liver), and 6.09 (muscle), suggesting distribution to the liver and preferentially to fat.; [underlined: Isolated perfused livers from female rats exposed to vapor (180 min, concentrations not reported)]; - Uptake 3 times faster than for trans isomer, consistent with difference in partition coefficients. | Humans and laboratory animals: ND; [underlined: Rat tissue homogenates exposed to vapor (793–1,586 mg/m^3^ for 1–4 h)]; - The tissue:air partition coefficients determined for rats in vitro were 148 (fat), 8.96 (liver), and 3.52 (muscle), suggesting distribution to the liver and preferentially to fat.; [underlined: Isolated perfused livers from female rats exposed to vapor (180 min, concentrations not reported)]; - Uptake 3 times slower than for cis isomer, consistent with difference in partition coefficients. | Humans: ND; Laboratory animals:; [underlined: Rats exposed to vapor (40 or 8,000 mg/m^3^ for 72 h)]; - Preferential distribution to liver and kidney, with only small amounts of [^14^C] in other tissues. | Humans and laboratory animals:; - Distributed throughout the body, with highest concentrations in fat, liver, brain, and kidney.; [underlined: Rats exposed via nose- only inhalation (340 or 3,400 mg/m^3^ for 2 h)]; - Accumulates in fat; only slowly released from fat with half-time of ~25 h.; [underlined: Pregnant rats exposed to vapor in a closed chamber (136–6,782 mg/m^3^ and for 1–6 h)]; - Found in milk in proportion to fat content (higher in rats vs. humans).; [underlined: Pregnant mice exposed to vapor (100 μCi for 10 min or 1 h; maternal blood concentrations ~230 μmol/L immediately following exposure)]; - Crosses placenta; distributes to fetus and amniotic fluid.; - Crosses blood:brain barrier. | Humans and laboratory animals:; - Rapidly distributed to brain, liver, lung, and preferential accumulation to fat.; - Found in milk.; - Crosses placenta; detected in neonatal blood. | Humans: ND; Laboratory animals:; [underlined: Rats exposed to vapor in a closed system (256 mg/m^3^ for 6 h)]; - Rapidly distributed throughout body, with highest levels in liver and kidney.; [underlined: Pregnant rats exposed to vapor (single dose of 511, 1,789, or 3,067 mg/m^3^ for 2.5 h)]; - Crosses placenta; distributes to fetus and amniotic fluid.; [underlined: Rats exposed to vapor (12,781 mg/m^3^ for 6 h/d, 5 d/wk for 7 wk)]; - Not expected to accumulate due to rapid metabolism and elimination.
Metabolism
Rate; primary reactive metabolites | Humans: ND; Laboratory animals:; - Rapid.; - Saturable.; - CYP450-mediated oxidation (primarily CYP2E1).; [underlined: Isolated perfused livers from female rats exposed to vapor (180 min, concentrations not reported); liver microsomes from male rats exposed in vitro (7.2 mM for 30 min)]; - Suicide inhibitor of CYP450 (less potent than trans isomer).; - Primary oxidation product is an unstable epoxide intermediate that spontaneously rearranges to form 2,2-dichloro-acetaldehyde, which is enzymatically converted to 2,2-dichloroethanol (primarily) and DCA, which may undergo oxidative dechlorination to glyoxylic acid.; - Metabolite production is faster and quantities are greater than for the trans isomer (by 4–25 times).; - Metabolites are not thought to undergo GSH conjugation to any major extent. | Humans: ND; Laboratory animals:; - Rapid.; - Saturable.; - CYP450-mediated oxidation (primarily CYP2E1).; [underlined: Isolated perfused livers from female rats exposed to vapor (180 min, concentrations not reported); liver microsomes from male rats exposed in vitro (7.2 mM for 30 min)]; - Suicide inhibitor of CYP450 (more potent than cis isomer).; - Primary oxidation product is an unstable epoxide intermediate that spontaneously rearranges to form 2,2-dichloro-acetaldehyde, which is enzymatically converted to 2,2-dichloroethanol and DCA (primarily), which may undergo oxidative dechlorination to glyoxylic acid.; - Metabolite production is slower and quantities are lower than for the cis isomer (by 4–25 times).; - Metabolites are not thought to undergo GSH conjugation to any major extent. | Humans and laboratory animals:; - Rapid.; - Saturable.; - CYP450-mediated oxidation (primarily CYP2E1).; - Primary oxidation products are 1,1-dichloroethene- epoxide (major), 2-chloroacetyl chloride (minor), and 2,2-dichloro- acetaldehyde (minor), all of which undergo hydrolysis or conjugation with GSH.; - GSH conjugates are catabolized in the kidney to a variety of urinary elimination products. | Humans and laboratory animals:; - Undergoes only limited metabolism (in humans, >80% of absorbed dose [any route] eliminated as unchanged parent).; - Saturable.; - Two competing biotransformation pathways: (1) CYP450- mediated oxidation (primary) and (2) GSH conjugation of parent compound.; - CYP450-mediated oxidation (primarily CYP2E1): initial product is unstable intermediate (Perc-Fe-O) that is converted to trichloroacetyl chloride (hydrolyzed to TCA with further metabolism to DCA) or oxalic acid, possibly via an unstable epoxide intermediate.; - GSH conjugation: yields trichlorovinyl cysteine, which can be bioactivated to form reactive species and DCA via beta-lyase or flavin-containing monooxygenases. | Humans and laboratory animals:; - Extensively metabolized.; - Saturable.; - Two competing biotransformation pathways:; (1) CYP450- mediated oxidation (primary) and; (2) GSH conjugation of parent compound.; - CYP450-mediated oxidation (primarily CYP2E1): initial product is unstable intermediate (TCE-O-P450 complex) that spontaneously rearranges to form chloral and unstable TCE oxide, which then forms dichloro- acetyl chloride.; Further metabolism yields 2,2,2-trichloro- ethanol, TCA, DCA, and oxalic acid.; - GSH conjugation: yields dichlorovinyl cysteine, which can be bioactivated to form reactive species via beta-lyase or flavin-containing monooxygenases. | Humans and laboratory animals:; - Rapid.; - Saturable.; - CYP450-mediated oxidation (primarily CYP2E1).; - Primary oxidation product is an unstable epoxide intermediate (2-chloroethylene oxide) that spontaneously rearranges to form 2-chloro- acetaldehyde.; - The epoxide and 2-chloroacetaldehyd e are both conjugated with GSH to form cysteine derivatives that are excreted in the urine.
Elimination
Elimination half-time; route of elimination | Humans:; [underlined: Humans (n = 2) exposed to vapor in showers (10 min, absorbed doses = 1.19–2.34 μg)]; - Elimination half-times of 0.82–2.37 min for blood and 8.96–29.33 min for highly perfused tissues were estimated.; Laboratory animals: ND; - The metabolite, DCA, is expected to be broken down to CO2 and exhaled, along with trace amounts of 2,2-dichloroethanol. | Humans and laboratory animals: ND; - The metabolite, DCA, is expected to be broken down to CO2 and exhaled, along with trace amounts of 2,2-dichloroethanol. | Humans: ND; Laboratory animals:; [underlined: Rats exposed to vapor (40 or 8,000 mg/m^3^ for 72 h)]; - Rapid elimination after inhalation exposure, mostly as metabolites in urine with some unchanged parent compound exhaled in expired air.; - Elimination following inhalation was biphasic, with most material eliminated in rapid first phase; elimination half-times were 20 min and 4 h for unchanged parent compound in breath and 3 and 20 h for metabolites in urine.; [underlined: Rats exposed to vapor (793 mg/m^3^ for 6 h)]; - 75% of absorbed dose was excreted in urine, 6% in feces, 8% as CO2 in breath and 4% as unchanged parent compound in breath. | Humans:; [underlined: Human subjects (n = 6) exposed to vapor (488 or 977 mg/m^3^ for 4 h)]; - 80–100% of the total absorbed dose was exhaled as unchanged parent compound in three first-order phases with half-lives of 12–16, 30–40, and 55–65 h.; - <2% excreted as metabolites in urine, primarily TCA.; [underlined: Occupationally exposed humans (n = 13)]; - Biological half-life of Perc was ~6 d; [underlined: Human subjects (n = 6) exposed to vapor in a dynamic chamber (67, 136, or 271 mg/m^3^ for 6 h)]; - Elimination half-times were 45.6 h for TCA and 14.1 h for a trichlorovinyl cysteine derivative.; Laboratory animals:; - For some inhalation exposures, rats excrete more than humans as urinary metabolites, with shorter half-times (11 h for TCA and 7.5 h for a trichlorovinyl cysteine derivative at 68–271 mg/m^3^ for 6 h), and mice more than rats (62.5% of absorbed dose from a 6-h inhalation exposure of 68 mg/m^3^, versus 18.7% in rats). [underlined: Rats exposed to vapor (68–4,080 mg/m^3^ for 6 h)]; - Elimination is dose- dependent (68% of absorbed dose exhaled as parent compound, 3.6% exhaled as CO_2_, and 18.7% excreted as metabolites in urine at 68 mg/m^3^ vs. 88, 0.7, and 6%, respectively, at 4,080 mg/m^3^). | Humans:; [underlined: Human subjects exposed singly or sequentially to vapor (267–2,042 mg/m^3^ for 4 h on 1–5 d)]; - 11% of the absorbed dose was exhaled unchanged (half-time ~10 h), 2% was exhaled as trichloroethanol (half-time ~20 h), 58% was eliminated as urinary metabolites (primarily trichloroethanol and its glucuronide with half-time of ~10 h and TCA with half-time of ~52 h), and 30% was unaccounted for (likely stored in adipose tissue).; Laboratory animals:; [underlined: Rats and mice exposed to vapor (54 or 3,240 mg/m^3^ for 6 h)]; - Recovery of [^14^C] was 5% (9%) exhaled as CO2 , 63% (74%) excreted in urine, and 7% (4%) in feces for the low dose, with similar results in both species at the high dose.; [underlined: Rats exposed to vapor (270–1,340 mg/m^3^ for 8 h)]; - Elimination half-time for oxidative metabolites (total trichloro compounds) in urine was 14–17 h. | Humans:; [underlined: Human subjects exposed to vapor by gas mask (7.5–60 mg/m^3^ for 6 h)]; - 5–7% of the inhaled amount was exhaled as unchanged parent compound.; Laboratory animals:; - Rapid elimination after inhalation exposure, primarily as metabolites in urine up to metabolic saturation, with increasing exhalation of unchanged parent compound above saturation.; [underlined: Rats exposed to vapor (26–13,000 mg/m^3^ for 6 h)]; - In rats exposed for 6 h to 26 mg/m^3^, 70% of the initial dose was recovered in urine and 2% was exhaled as the parent compound. Respective recoveries were 56 and 12% at 2,600 mg/m^3^ and 27 and >50% at 13,000 mg/m^3^.; - Elimination half- times were 20–30 min for parent compound in breath and 4.1–4.6 h for metabolites in urine.
PBPK models available | Yes | Yes | Yes | Yes | Yes | Yes
References | U.S. EPA (2003); Lilly et al. (1998); Pleil and Lindstrom (1997); Gargas et al. (1989); Gargas et al. (1988); Sato and Nakajima (1987); Costa and Ivanetich (1984, 1982); Filser and Bolt (1979); Henschler and Bonse (1977); Bonse et al. (1975) | U.S. EPA (2003); Lilly et al. (1998); Gargas et al. (1989); Gargas et al. (1988); Sato and Nakajima (1987); Costa and Ivanetich (1984, 1982); Filser and Bolt (1979); Henschler and Bonse (1977); Bonse et al. (1975); Lehmann and Schmidt-Kehl (1936) | Dallas et al. (1983); Jones and Hathway (1978); Mckenna et al. (1978a); Mckenna et al. (1978b); Mckenna et al. (1977) | Chiu et al. (2007); Völkel et al. (1998); Byczkowski and Fisher (1994); Dallas et al. (1994); Ghantous et al. (1986); Schumann et al. (1980); Monster et al. (1979b); Pegg et al. (1979); Ikeda and Imamura (1973) | Dallas et al. (1991); Pellizzari et al. (1982); Monster et al. (1979a); Astrand and Ovrum (1976); Monster et al. (1976); Muller et al. (1974); Ikeda and Imamura (1973); Laham (1970) | Krajewski et al. (1980); Ungváry et al. (1978); Bolt et al. (1977); Bolt et al. (1976); Watanabe et al. (1976); Withey (1976)

a When possible, exposure concentrations are reported in units of mg/m^3^ to enable interstudy comparisons. Concentrations reported in parts per million were converted to mg/m^3^ using: concentration in ppm × molecular weight (g/mol)] ÷ 24.45 (L/mol).

ADME = absorption, distribution, metabolism, and excretion; cis-1,2-DCE = cis-1,2-dichloroethylene; CO2 = carbon dioxide; CYP450 = cytochrome P450; DCA = 2,2-dichloroacetic acid; GSH = glutathione; ND = no data; Perc = tetrachloroethylene; PBPK = physiologically based pharmacokinetic; TCA = trichloroacetic acid; TCE = trichloroethylene; trans-1,2-DCE = trans-1,2-dichloroethylene.

No in vivo human or animal studies reporting distribution of cis-1,2-DCE were identified (U.S. EPA, 2020, 2010). Based on tissue:air partition coefficients and in vitro studies, cis- and trans-1,2-DCE are expected to distribute from the blood to the liver and preferentially to fat (U.S. EPA, 2010). The fat, liver, and muscle tissue:air partition coefficients for cis-1,2-DCE are ∼2-fold greater than those for the trans isomer, suggesting that the cis isomer is taken up more efficiently by these tissues (U.S. EPA, 2010). For the candidate analogues with data, distribution is rapid and widespread throughout the body, although differences in partitioning are observed. Perc and TCE primarily accumulate in fat and are also found in milk, which has a high fat content (ATSDR, 2019b, c; U.S. EPA, 2012, 2011d). In contrast, the highest levels of 1,1-DCE and vinyl chloride are found in the liver and kidneys, with only small amounts in other tissues and little to no accumulation in fat (ATSDR, 2019a, 2006; U.S. EPA, 2002b, 2000). Perc, TCE, and vinyl chloride have been shown to cross the placenta. Distribution to the placenta and the fetus has not been evaluated for the other compounds (ATSDR, 2019a; U.S. EPA, 2010).

Similar to cis-1,2-DCE, all of the candidate analogues undergo oxidative metabolism mediated by cytochrome P450 (CYP450) enzymes (primarily CYP2E1), and metabolism is saturable. For both cis- and trans-1,2-DCE, the initial oxidation product is an unstable epoxide intermediate that rearranges to form 2,2-dichloroacetaldehyde, which is then enzymatically converted to 2,2-dichloroethanol and 2,2-dichloracetic acid (U.S. EPA, 2020, 2010). Comparing cis- and trans-1,2-DCE, quantitative differences in the rate and quantity of metabolites produced have been noted, with the overall rate of metabolism faster and metabolite production greater for the cis isomer by approximately 4−25 times (U.S. EPA, 2020, 2010; ATSDR, 1996). In addition, the relative levels of metabolic products differ, so that 2,2-dichloroethanol is the major metabolite for the cis isomer, while DCA is the more abundant metabolite for the trans isomer (although due to the overall difference in metabolic rate, production of DCA from the cis isomer is still greater). Both isomers are capable of irreversible inhibition (i.e., suicide inactivation) via binding to the heme molecule on CYP450s, although cis-1,2-DCE is a less potent inhibitor than trans-1,2-DCE (U.S. EPA, 2010). Distinct from the other compounds under consideration, the downstream metabolites of the cis and trans isomers are not thought to undergo GSH conjugation to any major extent. Oxidation of 1,1-DCE generates three products, including an epoxide, and vinyl chloride oxidation generates an epoxide intermediate that rearranges to 2-chloroacetaldehyde; all of these products undergo hydrolysis and/or conjugation with GSH. GSH conjugation has been shown to contribute to the detoxification of 1,1-DCE and vinyl chloride (ATSDR, 2019a, 2006; U.S. EPA, 2002b, 2000). Perc and TCE are the only candidates having a competing GSH conjugation pathway independent of CYP450 oxidation. Metabolites from these GSH conjugation pathways can be bioactivated, yielding reactive species that contribute to the toxicity of these two compounds (ATSDR, 2019b, c). Compared with cis-1,2-DCE and to the other candidate analogues, less of the absorbed Perc is metabolized. In humans, 80−100% of the absorbed Perc dose remained unmetabolized and was exhaled as the parent compound (ATSDR, 2019a; U.S. EPA, 2012).

Elimination of cis-1,2-DCE is biphasic, with an initial rapid elimination from blood (half-time of 0.82−2.37 minutes in humans) followed by a second only slightly slower phase of elimination from highly perfused tissues (half-time of 8.96−29.33 minutes in humans) (U.S. EPA, 2010). Based on structural and physicochemical similarity to the cis isomer, elimination of trans-1,2-DCE is also expected to be reasonably rapid, although potentially longer than that of cis-1,2-DCE due to its slower rate of metabolism. Data in humans and/or laboratory animals show rapid elimination (minutes to a few hours) following inhalation exposure to 1,1-DCE and vinyl chloride (ATSDR, 2019a, 2006). Elimination half-times were significantly longer (10 hours to a few days) for Perc and TCE, indicating delayed clearance, presumably due to retention in fat (ATSDR, 2019b, c). For the candidate analogues with data, the primary routes of elimination are as metabolites in urine and via exhalation of unchanged parent compound in breath, with relative importance being dose dependent (increasing exhalation of unchanged parent compound as the exposure level increases above metabolic saturation). Perc differs from the other candidate analogues in that even at low exposure levels below metabolic saturation, elimination occurs primarily by exhalation of parent compound, with lesser amounts excreted as metabolites in the urine (ATSDR, 2019b).

Among the candidate analogues, trans-1,2-DCE appears to be the closest metabolic analogue to cis-1,2-DCE on the basis of rapid uptake and similarities in distribution and metabolism patterns. However, quantitative differences between the isomers, in uptake and in the rate and quantity of metabolites produced, could have implications for relative toxicity of the two compounds. Although Perc and TCE were identified as candidate analogues for cis-1,2-DCE based on the shared DCA metabolite, there are important differences between these candidate analogues and cis-1,2-DCE. Unlike cis-1,2-DCE, which is rapidly metabolized, Perc undergoes only limited metabolism. Additionally, metabolism of both Perc and TCE includes a direct GSH conjugation pathway independent of CYP450 oxidation that yields reactive species thought to contribute significantly to the toxicity of these two compounds (ATSDR, 2019b, c). Based on these metabolic differences, Perc and TCE are less suitable metabolic analogues for cis-1,2-DCE than the other candidate analogues.

### Toxicodynamic Similarity Comparisons

Table A-5 summarizes the inhalation toxicity values for the cis-1,2-DCE candidate analogues, and Table A-6 shows a comparison of the inhalation toxicity data for the candidate analogues in selected target organs/systems. Because inhalation data for cis-1,2-DCE are limited to an acute lethality study, oral data for cis-1,2-DCE were also considered when making comparisons across chemicals. Additional information, including more detailed discussions of possible mechanisms of toxicity, can be found in recent assessments for these chemicals (U.S. EPA, 2020; ATSDR, 2019a, b, c; U.S. EPA, 2012, 2011d, 2010; ATSDR, 2006; U.S. EPA, 2002b, 2000; ATSDR, 1996).

Table A-5 Comparison of Available Inhalation Toxicity Values for cis-1,2-DCE (CASRN 156-59-2) and Candidate Analogues^a^

Chemical; CASRN | cis-1,2-DCE; 156-59-2 | trans-1,2-DCE; 156-60-5 | 1,1-DCE; 75-35-4 | Perc; 127-18-4 | TCE; 79-01-6 | Vinyl Chloride; 75-01-4
Structure | Comparison of Available Inhalation Toxicity Value for cis-1,2-DCE and Candidate Analogues Chemical Structure for cis-1,2-DCE | Comparison of Available Inhalation Toxicity Value for cis-1,2-DCE and Candidate Analogues Analogue Chemical Structure for trans-1,2-DCE | Comparison of Available Inhalation Toxicity Value for cis-1,2-DCE and Candidate Analogues Analogue Chemical Structure for 1,1-DCE | Comparison of Available Inhalation Toxicity Value for cis-1,2-DCE and Candidate Analogues Analogue Chemical Structure for Perc | Comparison of Available Inhalation Toxicity Value for cis-1,2-DCE and Candidate Analogues Analogue Chemical Structure for TCE | Comparison of Available Inhalation Toxicity Value for cis-1,2-DCE and Candidate Analogues Analogue Chemical Structure for Vinyl Chloride
Role | Target | Analogue | Analogue | Analogue | Analogue | Analogue
DTXSID | 2024030 | 7024031 | 8021438 | 2021319 | 0021383 | 8021434
Repeat-dose toxicity—subchronic
POD (mg/m^3^) | NA | 109 | 0.170 | 11.53 | 0.177 (1st study) 0.020 (2nd study) | 2.56
POD type | NA | BMCL_1SDHEC_ | BMCL_10HEC_ | LOAEL | HEC_99_ (based on calculated idPODs) | LEC_10HEC_
Subchronic UF_C_ | NA | 300 (UF_A_ = 3; UF_H_ = 10; UF_D_ = 10) | 30 (UF_A_ = 3; UF_H_ = 10) | 300 (UF_H_ = 10; UF_L_ = 10; MF = 3 for database deficiencies) | 1st study: 100 (UF_L_ = 10; UF_A_ = 3.16; UF_H_ = 3.16) 2nd study: 10 (UF_A_ = 10) | 30 (UF_A_ = 3; UF_H_ = 10)
Subchronic p-RfC or Intermediate MRL (mg/m^3^)^b^ | NA | 4 × 10^−1^ (screening) | 4 × 10^−3^ (provisional) | 4 × 10^−2^ | 2 × 10^−3^ (midpoint RfC from two candidate RfCs) | 8 × 10^−2^
Critical effects | NA | Decreased WBC and lymphocyte counts | Atrophy in nasal olfactory epithelium | Color vision loss | Decreased thymus weight and fetal heart malformations | Centrilobular hypertrophy
Species | NA | Rat | Rat | Human | Mouse (1st study) Rat (2nd study) | Rat
Duration | NA | 90 d | 14 wk | Average 106 mo | Simulation-52 wk (1st study) GDs 1–22 (2nd study) | From 10 wk prior to mating through lactation
Route (method) | NA | Inhalation (whole body) | Inhalation (whole body) | Inhalation (worker breathing zone) | Oral (drinking water) | Inhalation (whole body)
Source | NA | U.S. EPA (2020) | ATSDR (2019a) | ATSDR (2019b) | ATSDR (2019c) | ATSDR (2006)
Repeat-dose toxicity—chronic
POD (mg/m^3^) | NA | 109 | 6.9 | 15 (1st study) 56 (2nd study) | 0.177 (1st study) 0.020 (2nd study) | 2.5
POD type | NA | BMCL_1SDHEC_ | BMCL_HEC_ | LOAEL | HEC_99_ (based on calculated idPODs) | NOAEL_HEC_ (based on idPODs)
Chronic UF_C_ | NA | 3,000 (UF_A_ = 3; UF_H_ = 10; UF_D_ = 10; UF_S_ = 10) | 30 (UF_A_ = 3; UF_H_ = 10) | 1,000 (UF_H_ = 10; UF_L_ = 10; UF_S_ = 10) | 1st study: 100 (UF_L_ = 10; UF_A-pk_ = 3; UF_H-pk_ = 3) 2nd study: 10 (UF_A_ = 3; UF_H_ = 3) | 30 (UF_A_ = 3; UF_H_ = 10)
Chronic RfC/p-RfC or chronic MRL (mg/m^3^)^b^ | NA | 4 × 10^−2^ (screening) | 2 × 10^−1^ | 4 × 10^−2^ (midpoint of the range from two studies) | 2 × 10^−3^ (midpoint RfC from two candidate RfCs) | 1 × 10^−1^
Critical effects | NA | Decreased WBC and lymphocyte counts | Liver toxicity (fatty change) | Cognitive and reaction time changes and color vision changes | Decreased thymus weight and fetal heart malformations | Liver cell polymorphisms and cysts
Species | NA | Rat | Rat | Human | Mouse (1st study) Rat (2nd study) | Rat
Duration | NA | 90 d | up to 18 mo | Mean 8.8 yr (1st study); 15 yr (2nd study) | Simulated 100 wk (1st study); GDs 1–22 (2nd study) | Lifetime
Route (method) | NA | Inhalation (whole body) | Inhalation (whole body) | Inhalation (workplace exposure) | Oral (drinking water) | Oral (feed)
Source | NA | U.S. EPA (2020) | U.S. EPA (2002b) | ATSDR (2019b); U.S. EPA (2012) | ATSDR (2019c); U.S. EPA (2011d) | U.S. EPA (2000)
Acute inhalation lethality data (LC_50_)
Rat inhalation LC_50_ (mg/m^3^) (lowest observed) | 54,320 | 95,556 | 25,178 | 34,200 | 67,172 | 460,113
Mouse inhalation LC_50_ (mg/m^3^) (lowest observed) | 65,500 (LC_Lo_) | NA | 200 | 35,269 | 45,408 | 294,000
Source | NLM (2021b); Kelly et al. (2000); Lehmann and Schmidt-Kehl (1936) | NLM (2021d); Kelly et al. (2000); Lehmann and Schmidt-Kehl (1936) | NLM (2021a); U.S. EPA (2021a); Siegel et al. (1971) | NLM (2021c); Pozzani et al. (1959); Friberg et al. (1953) | NLM (2021e): U.S. EPA CompTox Chemicals Dashboard (trichloroethylene, CASRN 79-01-6); https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID0021383#toxicity-values; accessed July 1, 2021 | NLM (2021f); U.S. EPA (2021b); Clark and Tinston (1982)

a U.S. EPA derived toxicity values are reported. In instances where no U.S. EPA toxicity value is available, ATSDR MRL values are shown. If U.S. EPA and ATSDR values were the same, both sources are noted.

b For 1,1-DCE, the U.S. EPA chronic RfC is shown. However, a more recent ATSDR assessment (ATSDR, 2019a) was done that reviewed new studies not available in the U.S. EPA (2002b) Toxicological Review. One of these new studies was used to derive a chronic MRL of 2 × 10^−3^ mg/m^3^; POD = 0.67 mg/m^3^ (BMCL_10HEC_); UF_C_ = 30; based on metaplasia in nasal olfactory epithelium in a 105-wk whole-body inhalation study in mice.

1,1-DCE = 1,1-dichloroethylene; ATSDR = Agency for Toxic Substances and Disease Registry; BMCL = benchmark concentration lower confidence limit; BMCL_10_ = 10% benchmark concentration lower confidence limit; cis-1,2-DCE = cis-1,2-dichloroethylene; DTXSID = DSSTox substance identifier; GD = gestation day; HEC = human equivalent concentration; HEC_99_ = 99th percentile human equivalent concentration; idPOD = internal dose points of departure; LC_50_ = median lethal concentration; LC_Lo_ = lowest lethal concentration; LEC_10_ = 10% lowest effect concentration; LOAEL = lowest-observed-adverse-effect level; MF = modifying factor; MRL = minimal risk level; NA = not applicable; NOAEL = no-observed-adverse-effect level; p-RfC = provisional reference concentration; Perc = tetrachloroethylene; pk = uncertainty based on pharmacokinetic component; POD = point of departure; RfC = reference concentration; SD = standard deviation; TCE = trichloroethylene; trans-1,2-DCE = trans-1,2-dichloroethylene; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor; U.S. EPA = U.S. Environmental Protection Agency; WBC = white blood cell.

Table A-6 Comparison of Effects on Target Organs/Systems Following Short-term, Subchronic, and Chronic Exposure to cis-1,2-DCE (Oral) and Candidate Analogues (Inhalation)^a,b^

Target Organ/System | cis-1,2-DCE^c^ | trans-1,2-DCE | 1,1-DCE | Perc | TCE^d^ | Vinyl Chloride^d^
Target Organ/System | Effect^e,f,g^ (species)
Liver | In 14- and 90-d studies in rats (10/sex/dose; Sprague Dawley) exposed orally (gavage; 0−1,940 mg/kg-d; 97% purity), relative increases in liver weight were observed (3−39% increases). In the 14-d study, statistically significant increases were observed in both absolute and relative liver weights (15−21%) in females and in relative liver weights (16%) in males at ≥97 mg/kg-d. In the 90-d study, relative liver weight increases (14−15%) were statistically significant in both females and males at ≥97 mg/kg-d. Refer to Table 3 in the main document for more details. (rat, oral, short-term and subchronic) | In 8- and 16-wk studies in rats (6 females/dose; SPR Wistar) exposed to vapor (793 mg/m^3^; 8 h/d, 5 d/wk), fatty degeneration of the liver lobule and Kupffer cells were observed. In the 8-wk study, 3 of 6 exposed rats showed slight changes in the liver lobules and severe changes in the Kupffer cells, while severe fat accumulation was also noted in the Kupffer cells in 1 of 6 controls. In the 16-wk study, 3 of 6 exposed rats showed severe changes in liver lobules and slight changes in Kupffer cells and 2 of the other exposed rats showed slight changes in both the liver lobules and Kupffer cells. Of the 6 controls, 2 also showed slight changes in both the liver lobules and Kupffer cells in the 16-wk study. (rat, inhalation, subchronic and chronic) | In a 14-wk study, male rats (10/sex/dose; F344/N) exposed to vapor (0−396 mg/m^3^; 6 h/d, 5 d/wk) exhibited hepatic centrilobular cytoplastic alterations at ≥50 mg/m^3^. (rat, inhalation, chronic); In 6-, 12-, and 18-mo studies, rats (86/group; Sprague Dawley) exposed to vapor (40 and 160 mg/m^3^ for the first 5 wk, then 100 and 300 mg/m^3^ for the remainder; 6 h/d, 5 d/wk) exhibited hepatocellular midzonal fatty changes at the high dose after 6 and 12 mo (males and females), and at the high dose at 18 mo (females only); changes were reversible. (rat, inhalation, chronic)^h^; In a 12-d study, mice (10/sex/dose; Ha[ICR]) exposed to vapor (0−793 mg/m^3^; 6 h/d, 5 d/wk) exhibited increased relative liver weights (by 20−24%) at ≥218 mg/m^3^. (mouse, inhalation, short-term); In a 5-d study, mice (4−10 males/dose; CD-1) exposed to vapor (0−238 mg/m^3^; 22−23 h/d) exhibited hepatocellular degeneration at ≥59 mg/m^3^. (mouse, inhalation, short-term) | In a population of 27 dry cleaners (107 mg/m^3^ 8-h TWA exposure; 12-yr mean duration) and 26 nonexposed laundry workers, a higher prevalence of diffuse parenchymal changes was observed among the laundry workers (67 vs. 38% in the control group). (human); In a 30-d study, mice (10−12/sex/dose; NMRI) exposed to vapor (0−1,017 mg/m^3^; 24 h/d, continuous) exhibited liver enlargement and vacuolization of hepatocytes at ≥61 mg/m^3^. (mouse, inhalation, short-term) | In a 30-d study, male mice (10−20/sex/dose; NMRI) exposed to vapor (0−1,612 mg/m^3^; 24 h/d, continuous) exhibited increased liver weight and increased BuChE activity, accompanied by misshapen, enlarged and vacuolated hepatocytes at ≥403 mg/m^3^ (in female mice, these effects occurred at 1,612 mg/m^3^). (mouse, inhalation, short-term) | In a 19-wk study in rats (30/sex/dose; Sprague Dawley) exposed to vapor (0−2,812 mg/m^3^; 6 h/d, 10 wk prior to mating through lactation), centrilobular hypertrophy was observed in F_1_ female rats at ≥26 mg/m^3^. (rat, inhalation, reproductive) ^i^
Kidney | In 14- and 90-d studies in rats (10/sex/dose; Sprague Dawley) exposed orally (gavage; 0−1,940 mg/kg-d; 97% purity), relative increases in kidney weight were observed (12−27% increases). In the 14-d study, absolute and relative kidney weights were statistically significantly increased in females (14−20%) at ≥970 mg/kg-d; in males, increases in absolute and relative kidney weights did not reach statistical significance at any dosing level (97−1,940 mg/kg-d).; In the 90-d study, increases in relative and absolute kidney weights (3−23%) did not reach statistical significance in females; however, in males, increases in relative (but not absolute) kidney weight (14%) were statistically significant at ≥32 mg/kg-d. Refer to Table 3 in the main document for more details. (rat, oral, short-term and subchronic)^j^ | In a 90-d study in rats (15/sex/dose; Crl:CD BR) exposed to vapor (793−15,860 mg/m^3^; 6 h/d, 5 d/wk; >99.4% purity), increases in relative kidney weights for male and females were <10% and not generally dose-related. (rat, inhalation, subchronic) | In a 14-wk study, female mice (10/sex/dose; B6C3F1/N) exposed to vapor (0−396 mg/m^3^; 6 h/d, 5 d/wk) exhibited increased relative kidney weights (by 11%) at ≥25 mg/m^3^. (mouse, inhalation, chronic); Enzyme changes (↓ kidney monooxygenase and epoxide hydrolase levels), tubular alterations, and kidney histopathology were observed at higher exposure levels. | In a population of 57 dry cleaners (68 mg/m^3^; 8-h TWA exposure; 13.9-yr mean duration; mostly females), 30 unexposed workers (mostly females), and 81 unexposed workers (mostly males), a 50% increase in creatinine- adjusted geometric mean concentration of urinary β2 glucuronidase and a 100% increase in geometric mean urinary lysozyme were observed in dry cleaners compared with either control group. (human); In a 103-wk study, mice (49−50/sex/dose; B6C3F1) exposed to vapor (0−1,356 mg/m^3^; 6 h/d, 5 d/wk) exhibited nephrosis at ≥678 mg/m^3^. (mouse, inhalation, chronic); ↑ Kidney weight and histopathology were observed at higher exposure levels. | In a 30-d study, male mice (10−20/sex/dose; NMRI) exposed to vapor (0−1,612 mg/m^3^; 24 h/d, continuous) exhibited increased kidney weight (by 39%) at ≥403 mg/m^3^ (in female mice, the effect occurred at 1,612 mg/m^3^). (mouse, inhalation, short-term); ↑ Urinary glucose and proteins, serum gamma-glutamyl transpeptidase; and blood urea nitrogen, and kidney histopathology were observed at higher exposure levels. | In a 12-mo study, male rats (75/dose; Wistar) exposed to vapor (0−7,668 mg/m^3^; 6 h/d, 6 d/wk) exhibited increased kidney weights at ≥256 mg/m^3^. (rat, inhalation, chronic); No histopathology at highest exposure levels.
Respiratory | In a 14-d study, rats (5/sex/group; strain not specified) exposed to vapor (to 0−91,900 mg/m^3^ for 4 h) exhibited irregular respiration at ≥53,400 mg/m^3^ immediately following exposure. (rat, inhalation, acute) | In 1-, 2-, 8- and 16-wk studies in rats (6 females/dose; SPR Wistar) exposed to vapor (793 mg/m^3^; 8 h/d, 5 d/wk), slight pulmonary capillary hyperemia and alveolar septum distension were observed in all six rats in all four exposure duration groups. (rat, inhalation, acute and subchronic); In a 90-d study, rats (15/sex/group; Crl:CD [SD] BR) exposed to vapor (0−16,000 mg/m^3^; 6 h/d, 5 d/wk) exhibited no upper or lower respiratory lesions. (rat, inhalation, subchronic) | In a 14-wk study, rats (10/sex/dose; F344/N) exposed to vapor (0−396 mg/m^3^; 6 h/d, 5 d/wk) exhibited olfactory epithelium mineralization at 25 mg/m^3^; olfactory epithelium atrophy was also observed in males at ≥25 mg/m^3^. (rat, inhalation, subchronic)^k^; In a 105-wk study, mice (50/sex/dose; B6C3F1/N) exposed to vapor (0−100 mg/m^3^; 6 h/d, 5 d/wk) exhibited nasal turbinate atrophy, hyperostosis, and metaplasia of the respiratory olfactory epithelium at ≥25 mg/m^3^. (mouse, inhalation, chronic)^k^; In a 14-wk study, female mice (10/sex/dose; B6C3F1/N) exposed to vapor (0−396 mg/m^3^; 6 h/d, 5 d/wk) exhibited increased relative lung weights (by 12−16%) at ≥50 mg/m^3^. (mouse, inhalation, chronic); Hyperostosis, turbinate atrophy, chronic lung inflammation, respiratory epithelium hyperplasia, metaplasia, and necrosis and laryngeal lesions were noted at higher levels. | In a 103-wk study, mice (49−50/sex/dose; B6C3F1) exposed to vapor (0−1,356 mg/m^3^; 6 h/d, 5 d/wk) exhibited acute passive congestion of the lungs at ≥678 mg/m^3^. (mouse, inhalation, chronic); Erosion of the nasal mucosa, thrombosis, and squamous metaplasia in the nasal cavity were observed at higher levels. | In 28- and 90-d studies, rats (Wistar) exposed to vapor (0−2,021 mg/m^3^; 4 h/d, 5 d/wk) exhibited lung lesions (bronchiolitis and alveolitis) at 2,021 mg/m^3^. (rat, inhalation, short-term and subchronic); No noncancer lung effects were observed in chronic studies at higher levels. | In a 5- to 6-mo study, male mice (3−13/dose; CD-1) exposed to vapor (0−15,337 mg/m^3^; 5 h/d, 5 d/wk) exhibited proliferation and hypertrophy of bronchial epithelium, hypersecretion of mucin, and hyperplasia of alveolar epithelium at ≥6,390 mg/m^3^. (mouse, inhalation, chronic)
Neurological | ND | ND | ND | In 65 households in buildings collocated with dry cleaners (65 children; geometric mean exposure 0.34 mg/m^3^; 10-yr mean duration of residence) and 61 households in residential buildings without dry cleaners (71 children), decreased visual contrast sensitivity and color vision impairment was observed for exposed subjects compared to controls. (human)^l^; In a 90-d study, gerbils (4/sex/dose; Mongolian) exposed to vapor (0−407 mg/m^3^; 24 h/d, continuous) exhibited decreased DNA content in the frontal cortex at ≥407 mg/m^3^. (gerbil, inhalation, subchronic); Changes in fatty acid composition in the brain, ↓ brain weight, ↓ activity, changes in auditory response, and ↑ amplitude of flash evoked potential peak N3 were observed at higher exposure levels. | In a 13-wk study, male rats (5/dose; JCL-Wistar) exposed to vapor (0−1,612 mg/m^3^; 8 h/d, 5 d/wk) exhibited decreased wakefulness during exposure and a decreased postexposure sleeping heart rate at ≥269 mg/m^3^. (rat, inhalation, chronic); ↓ Swimming speed, ↑ auditory threshold, depressed amplitude of auditory-evoked potentials, latency in visual discrimination response, ↓ shock avoidance and startle response, behavioral changes, and astroglial hypertrophy were observed at higher exposure levels. | In a 20-wk study, rats (90/sex/dose; F344) exposed to vapor (0−128 mg/m^3^; 1 h/d, 5 d/wk) exhibited no neurological effects. (rat, inhalation, chronic)
Hematological (red cell) | In 14- and 90-d studies in rats (10/sex/dose; Sprague Dawley) exposed orally (gavage; 0−1,940 mg/kg-d; 97% purity), small decreases in RBC, hematocrit and hemoglobin—not deemed to be biologically significant—were observed. In the 14-d study, no significant changes in hemoglobin or RBC counts were observed at any dose level (97−1,940 mg/kg-d), but significant decreases (11%) in hematocrit were observed in females at 291 mg/kg-d.; In the 90-d study, decreases in hemoglobin and RBC counts (6−8%) were significant at 291 mg/kg-d in females; decreases in hematocrit in females (10%) and hemoglobin in males (6%) were significant at ≥291 mg/kg-d. Refer to Table 3 in the main document for more details. (rat, oral, short-term and subchronic) | In a 90-d study, rats (15/sex/dose; Crl:CD BR) exposed to vapor (0−15,860 mg/m^3^; 6 h/d, 5 d/wk; >99.4% purity) showed decreased mean hemoglobin (in males) at ≥3,965 mg/m^3^ after 45 d. In females, mean monocyte count was decreased at 15,860 mg/m^3.^after 45 d; these changes were not considered toxicologically important and did not occur at the 90-d sampling time. (rat, inhalation, subchronic) | In 6-, 12-, and 18-mo studies in rats (86/group; Sprague Dawley) exposed to vapor (40 and 160 mg/m^3^ for the first 5 wk, then 100 and 300 mg/m^3^ for the remainder; 6 h/d, 5 d/wk), no hematological effects were observed. (rat, inhalation, chronic) | In a population of dry cleaners (135 mg/m^3^, 8-h TWA geometric mean exposure; 1- to 12-mo duration; 29 men and 27 women), and unexposed workers (30 men and 35 women), no hematological effects were observed. (human); In a 104-wk study in rats (50/sex/dose; F344) exposed to vapor (0−4,070 mg/m^3^; 6 h/d, 5 d/wk), the only hematology change noted was an increase in mean corpuscular hemoglobin in female rats exposed to 4,070 mg/m^3^. (rat, inhalation, chronic) | In a 4-wk study, female rats (8/dose; Sprague Dawley) exposed to vapor (0−5,374 mg/m^3^; 6 h/d, 4 d/wk; 99.99% purity) showed no hematological effects at 5,374 mg/m^3^. (rat, inhalation, short-term) | In an 8-wk study, male mice (4/dose; CD-1) exposed to vapor (0−2,600 mg/m^3^; 6 h/d, 5 d/wk) showed no hematological effects at 2,600 mg/m^3^. (mouse, inhalation, subchronic)
Immunological | ND | In 8- and 16-wk studies in rats (6 females/dose; SPR Wistar) exposed to vapor (793 mg/m^3^; 8 h/d, 5 d/wk), severe pneumonic infiltration (not further characterized) was observed in the lungs of 3/6 exposed rats at both exposure durations but not in controls. (rat, inhalation, subchronic and chronic); In a 90-d study in rats (15/sex/dose; Crl:CD BR) exposed to vapor (0−15,860 mg/m^3^; 6 h/d, 5 d/wk; >99.4% purity), decreased WBC and lymphocyte counts (18−25%) were observed in exposed animals, reaching statistical significance in males at 15,860 mg/m^3^ after 45 d (WBC and lymphocyte counts) and 90 d (lymphocyte counts only). (rat, inhalation, subchronic)^m^ | ND | In a 4-wk study in female rats (8/dose; Sprague Dawley) exposed to vapor (0−6,793 mg/m^3^; 6 h/d, 5 d/wk; 99.98% purity), no immunological effects were observed. (rat, inhalation, short- term) | In a 30-d study, mice (10−20/sex/dose; NMRI) exposed to vapor (0−1,612 mg/m^3^; 24 h/d, continuous) exhibited decreased spleen weights (by 24−41%) at ≥1,612 mg/m^3^. (mouse, inhalation, short-term) ↓ Splenic anti-sRBC IgM response and ↓ serum IgG were observed at higher exposure levels. | In an 8-wk study, male mice (4/dose; CD-1) exposed to vapor (0−2,600 mg/m^3^; 6 h/d, 5 d/wk) exhibited an increase in spontaneous lymphocyte proliferation at ≥26 mg/m^3^. (mouse, inhalation, subchronic) ↑ Spleen weight and ↓ WBC counts were observed at higher exposure levels.
Developmental | ND | In a developmental study in rats (24 dams/dose; Crl:CD BR) exposed to vapor (0−47,580 mg/m^3^; 6 h/d, GDs 7−16), decreased fetal weight (by 4−6%) and a nonsignificant increase in hydrocephalus were observed at 47,580 mg/m^3^. (rat, inhalation, developmental) | In a developmental study in mice (15−65 dams/dose; CD-1) exposed to vapor (0−1,189 mg/m^3^; 22−23 h/d, GDs 6−16), incidence of fetuses with unossified incus and incompletely ossified sternebrae was increased at ≥59 mg/m^3^. (mouse, inhalation, developmental) | In developmental studies in rats (17−30 dams/dose; Sprague Dawley) and mice (17−30 dams/dose; Swiss- Webster) exposed to vapor (0−2,035 mg/m^3^; 7 h/d, GDs 6−15), increased fetal resorptions in rats and decreased fetal weight and delayed ossification in mice were observed at 2,035 mg/m^3^. (rat and mouse, inhalation, developmental) | In a developmental study in rats (30 dams/dose; Long-Evans) exposed to vapor (0−9,673 mg/m^3^; 6 h/d, 7 d/wk; GDs 0−20), decreased fetal weight and incomplete skeletal ossification were observed at 9,673 mg/m^3^. (rat, inhalation, developmental) | In developmental studies in mice (30−40 dams/dose; CF-1) exposed to vapor (0−1,278 mg/m^3^; 7 h/d, 10 d; GDs 6−15) and in rabbits (15−20 dams/dose; New Zealand) exposed to vapor (0−1,278 mg/m^3^; 7 h/d, 13 d; GDs 6−18), delayed ossification was observed at 1,278 mg/m^3^. (mouse and rabbit, inhalation, developmental)
References | DuPont Haskell Lab (1999); McCauley et al. (1995); McCauley et al. (1990) | Kelly (1998); Hurtt et al. (1993); DuPont (1988); Haskell Laboratories (1988); Freundt et al. (1977) | NTP (2015); Quast et al. (1986); Henck et al. (1979); Rampy et al. (1977); Short et al. (1977c); Short et al. (1977b); Short et al. (1977a) | Boverhof et al. (2013); Mcdermott et al. (2005); Brodkin et al. (1995); JISA (1993); Cai et al. (1991); Karlsson et al. (1987); Mennear et al. (1986); NTP (1986); Kjellstrand et al. (1984); Franchini et al. (1983); Schwetz et al. (1975); Storm et al. (2011) | Boverhof et al. (2013); Kumar et al. (2002); Arito et al. (1994); Kjellstrand et al. (1983); Dorfmueller et al. (1979) | Thornton et al. (2002); Bi et al. (1985); Hehir et al. (1981); John et al. (1981); Suzuki (1981); Sharma and Gehring (1979); Suzuki (1978); John et al. (1977)

a When possible, exposure concentrations are reported in units of mg/m^3^ to enable interstudy comparisons. Concentrations reported in parts per million were converted to mg/m^3^ using: concentration in ppm × molecular weight (g/mol)] ÷ 24.45 (L/mol).

b Duration categories are defined as follows: acute = exposure for ≤24 hours; short term = repeated exposure for 24 hours to ≤30 days; long-term (subchronic) = repeated exposure for >30 days to ≤10% life span for humans (>30 days up to approximately 90 days in typically used laboratory animal species); and chronic = repeated exposure for >10% life span for humans (>~90 days to 2 years in typically used laboratory animal species) (U.S. EPA, 2002a).

c No subchronic- or chronic inhalation data available; effects listed are following acute inhalation or oral exposure as noted.

d The subchronic and chronic inhalation toxicity values for TCE and the chronic toxicity value for vinyl chloride were derived following route-to-route extrapolations from oral studies (see Table A-5). Effects from oral studies on candidate analogues are not included here.

e The lowest LOAELs or highest NOAELs for effects on the target organ/system are shown; ≥ indicates that other effects were reported at concentrations greater than or equal to the lowest LOAEL. Selected effects observed at higher exposure concentrations are listed.

f Species where effects in the target organ/system were observed are shown in parentheses.

g Effects used for derivation of toxicity values shown in Table A-5 are in bold.

h Midzonal fatty changes, listed as an observed effect at higher exposure levels, formed the basis for the inhalation chronic RfC (U.S. EPA, 2002b), see Table A-5. The lowest LOAEL value shown is from new data reported in ATSDR (2019a).

i Basis for the inhalation intermediate MRL (ATSDR, 2006).

j Basis for chronic RfD derived by IRIS (U.S. EPA, 2010) and subchronic provisional p-RfD derived in a previous PPRTV assessment for cis-1,2-DCE (U.S. EPA, 2011c).

k Basis for the inhalation intermediate and chronic MRLs (ATSDR, 2019a). See Table A-5 footnote b regarding the chronic toxicity value for 1,1-DCE.

l Basis for the inhalation intermediate MRL and the chronic MRL and RfC (ATSDR, 2019b; U.S. EPA, 2012).

m Basis for the inhalation screening subchronic and chronic RfCs (U.S. EPA, 2020).

↑ = increased; ↓ = decreased; 1,1-DCE = 1,1-dichloroethylene; BuChE = plasma butyrylcholinesterase; cis-1,2-DCE = cis-1,2-dichloroethylene; DNA = deoxyribonucleic acid; GD = gestation day; IRIS = Integrated Risk Information System; LOAEL = lowest-observed-adverse-effect level; MRL = minimal risk level; ND = not determined; NOAEL = no-observed-adverse-effect level; Perc = tetrachloroethylene; PPRTV = Provisional Peer-Reviewed Toxicity Value; RBC = red blood cell; RfC = reference concentration; RfD = reference dose; sRBC = sheep red blood cell; TCE = trichloroethylene; trans-1,2-DCE = trans-1,2-dichloroethylene; WBC = white blood cell.

#### Acute Effects

The lowest observed inhalation median lethal concentration (LC_50_) values for cis-1,2-DCE are 54,320 and 65,500 mg/m^3^, in rats exposed for 4 hours and mice exposed for 2 hours, respectively (Kelly et al., 2000; Lehmann and Schmidt-Kehl, 1936). Inhalation LC_50_ values for candidate analogues ranged from 25,178 mg/m^3^ (1,1-DCE) to 460,113 mg/m^3^ (vinyl chloride) in rats and 200 mg/m^3^ (1,1-DCE) to 294,000 mg/m^3^ (vinyl chloride) in mice (see Table A-5). Although limited conclusions can be drawn from acute data, it is clear that the acute potency of cis-1,2-DCE is greater than that of vinyl chloride for exposure via inhalation. The LC_50_ value for trans-1,2-DCE (95,556 mg/m^3^) is within twofold of the LC_50_ value for cis-1,2-DCE (54,320 mg/m^3^) in rats exposed for 4 hours (Kelly et al., 2000).

#### Liver Effects

No inhalation studies evaluating the potential for cis-1,2-DCE to promote liver effects are available. Oral exposure to cis-1,2-DCE produced dose-related increases in absolute and/or relative liver weights in rats treated for 14 or 90 days, albeit without accompanying changes in serum chemistry or histopathology, even at the highest doses tested. Findings after oral exposure to trans-1,2-DCE were similar to those for the cis isomer, primarily involving increases in absolute and relative liver weight with limited clinical chemistry changes and no accompanying histopathology. Hepatic effects, including increases in absolute and relative liver weight, fatty changes, necrosis, and altered hepatocyte morphology, were also observed for the other candidate analogues by the oral route.

Liver effects have also been observed following inhalation exposure to each candidate analogue. Fatty degeneration in the liver lobule was observed in rats following repeated inhalation exposure to trans-1,2-DCE vapors. A supporting in vitro study on liver perfusates supplemented with either cis- or trans-1,2-DCE in the gas phase showed increasing levels of lactate dehydrogenase (LDH), aspartate aminotransferase (AST), and alanine aminotransferase (ALT) in the perfusate with time, indicative of liver damage (Bonse et al., 1975). The enzyme levels were higher in the cis-1,2-DCE-exposed perfusate compared with the trans-1,2-DCE-exposed perfusate. Acute oral and injection studies that tested liver and plasma enzyme levels in rats exposed to the cis- and trans-1,2-DCE isomers also showed somewhat greater effects from the cis isomer (Mcmillan, 1986; Jenkins et al., 1972).

For 1,1-DCE, prolonged inhalation exposure has been shown to produce liver lesions ranging from fatty change to necrosis in rats and mice, and hepatotoxicity was identified as the critical effect for derivation of the 1,1-DCE chronic reference concentration (RfC). Increased liver weight also was noted. Hepatotoxicity of 1,1-DCE has been attributed to metabolites that do not undergo GSH conjugation in the liver and covalently bind with tissue macromolecules. The 1,1-DCE metabolites 1,1-dichloroethene epoxide, 2-chloroacetyl chloride, and 2,2-dichloroacetaldehyde, when unconjugated, are presumed hepatic toxicants (ATSDR, 2019a). The 1,1-DCE oxidation product 2,2-dichloroacetaldehyde is shared with cis-1,2-DCE. Toxicity of 1,1-DCE is correlated with CYP2E1 concentrations and increases under conditions of GSH depletion; however, fatty change, primarily in the centrilobular region, was observed in the absence of GSH depletion.

Hepatic lesions, such as centrilobular hypertrophy, and increased relative liver weight have also been reported for subchronic inhalation exposure to vinyl chloride, and this is the basis for the ATSDR intermediate minimal risk level (MRL). The chronic RfC is also based on hepatic effects, although by route-to-route extrapolation from chronic oral data. Vinyl chloride liver toxicity is thought to be related to the production of the reactive intermediate metabolites, 2-chloroethylene oxide and 2-chloroacetaldehyde, which are known to bind to liver proteins and macromolecules in liver tissue (ATSDR, 2006; U.S. EPA, 2000). Reactive intermediates from metabolism of cis- and trans-1,2-DCE are known to bind to the heme moiety of CYP450 molecules, and other data also show protein and lipid binding by metabolites of 1,2-DCE (isomer not stated) in liver microsomes (U.S. EPA, 2020). Both 1,2-DCE isomers and vinyl chloride have structural alerts for protein binding (see Figure A-1).

Both TCE and Perc have also been found to produce liver effects. Perc inhalation exposure resulted in parenchymal changes in humans and liver enlargement and vacuolization of hepatocytes in laboratory animals, while inhalation exposure to TCE caused increased liver weights, serum chemistry changes, and enlarged vacuolated hepatocytes. The Perc and TCE metabolite, DCA, which is also a metabolite of cis-1,2-DCE, has been linked to liver toxicity (ATSDR, 2019b), but Perc and TCE also generate other reactive metabolites that likely contribute to hepatotoxicity. Perc hepatotoxicity occurs even when CYP450 pathways are perturbed, suggesting that the alternative GSH conjugation pathway (and subsequent formation of reactive metabolites) likely contributes to this toxicity (ATSDR, 2019b). Much like Perc, reactive metabolites from the oxidation-independent GSH conjugation pathway also likely contribute to TCE hepatotoxicity (ATSDR, 2019c). Direct GSH conjugation of parent compound, as occurs for Perc and TCE, is not known to occur for cis-1,2-DCE.

#### Kidney Effects

No data are available on the potential for cis-1,2-DCE to cause kidney effects following inhalation exposure. In orally exposed rats, cis-1,2-DCE produced an increase in relative kidney weights in males not accompanied by supporting effects (e.g., histopathology or clinical chemistry changes), even at the highest dose. The increase in kidney weight is the basis for both the subchronic provisional reference dose (p-RfD) derived in a previous PPRTV assessment and the chronic reference dose (RfD) derived by IRIS for cis-1,2-DCE. Results similar to cis-1,2-DCE (increases in kidney weights without supporting changes in serum chemistry or histopathology) were observed following oral exposure to trans-1,2-DCE. Renal effects, including increases in kidney weight, increased blood urea nitrogen (BUN), cytomegaly, and toxic nephropathy were observed for the other candidate analogues by the oral route.

Increased kidney weights following inhalation exposure were observed for all candidate analogues except trans-1,2-DCE. Kidney weight increases were accompanied by additional evidence of renal toxicity, such as histological, serum chemistry, and/or urinalysis changes for 1,1-DCE, Perc, and TCE. 1,1-DCE kidney toxicity is thought to be associated with β-lyase bioactivation of hepatic GSH conjugates and/or their derivatives to reactive species (ATSDR, 2019a). For Perc and TCE, the toxic renal effects are thought to be due to the formation of reactive GSH-dependent metabolites following nonoxidative GSH conjugation with the parent compounds. Data suggest that GSH conjugation and the formation of GSH-dependent metabolites such as S-(1,2-dichlorovinyl)cysteine (1,2-DCVC) play a significant role in both Perc and TCE-induced renal toxicity (ATSDR, 2019b, c). GSH conjugation of the parent compound and formation of reactive GSH-dependent metabolites are not observed for cis-1,2-DCE.

#### Respiratory Effects

No subchronic- or chronic inhalation studies evaluating the potential for cis-1,2-DCE to cause respiratory effects are available, although irregular respiration was reported immediately after acute inhalation exposure to lethal levels of cis-1,2-DCE in rats (DuPont Haskell Lab, 1999). Following oral exposure, no clinical signs of respiratory distress or histopathology in the lung were observed; lungs were not weighed in the available study (McCauley et al., 1995; McCauley et al., 1990). Limited information is available about respiratory effects of candidate analogues following oral exposure, although gavage administration of TCE has been reported to cause dyspnea and pulmonary vasculitis.

Lung effects, including capillary hyperemia (vinyl chloride and trans-1,2-DCE) alveolar septum distention (TCE, vinyl chloride, and trans-1,2-DCE) congestion (vinyl chloride) bronchiolitis and alveolitis (Perc, TCE, vinyl chloride, and 1,1-DCE) and hyperplasia (Perc, TCE, and vinyl chloride) were observed in inhalation studies of all candidate analogues but only sporadically. 1,1-DCE and Perc were the only candidate analogues reported to produce upper respiratory effects following inhalation exposure, primarily lesions such as hyperplasia, metaplasia, and erosion of the nasal mucosa. Mineralization and atrophy of the olfactory epithelium in rodents was the basis for the intermediate and chronic inhalation MRL values for 1,1-DCE. Nasal lesions were not observed in rats exposed to trans-1,2-DCE at concentrations up to 15,860 mg/m^3^ for 90 days in a study that included histopathological examination of upper and lower respiratory tract tissues at all exposure levels (U.S. EPA, 2020).

#### Neurological Effects

No subchronic or chronic inhalation studies evaluating the potential for cis-1,2-DCE to cause neurological effects are available. Animals acutely exposed to lethal concentrations of cis-1,2-DCE vapors showed signs of CNS depression (DuPont Haskell Lab, 1999). No behavioral clinical signs or changes in brain weight or histopathology were observed in animals treated for 90 days with doses up to 872 mg/kg-day of cis-1,2-DCE by gavage (McCauley et al., 1995; McCauley et al., 1990).

Among candidate analogues, no data are available on neurological effects for trans-1,2-DCE or 1,1-DCE following repeated inhalation exposure, and negative results were observed in neurotoxicity testing on vinyl chloride. In contrast, neurotoxicity is a sensitive endpoint for Perc and has been demonstrated in humans. The intermediate inhalation MRL for Perc is based on color vision changes, while both the chronic inhalation MRL and the chronic RfC are based on cognitive and reaction time changes and color vision changes in humans. In animals, Perc induced various neurotoxic effects, including electrophysiological changes, auditory changes, and effects on the brain (ATSDR, 2019b). In general, the neurotoxic effects of Perc are thought to be due to the parent compound rather than metabolites (ATSDR, 2019b). TCE has also been shown to induce neurological effects, such as decreased wakefulness and sleeping heart rate, auditory changes, behavioral changes, visual changes, and astroglial hypertrophy in animal studies. The TCE metabolite, chloral hydrate, has been shown to act as a CNS depressant through inhibition of neuronal receptors (ATSDR, 2019c).

#### Hematological Effects (Red Blood Cell [RBC] Parameters)

No inhalation studies on cis-1,2-DCE evaluating hematological effects were identified. In oral studies, decreases in RBC, hemoglobin, and/or hematocrit were reported, but these changes were small in magnitude, not clearly related to dose, within the normal range of variation (U.S. EPA, 2010), and possibly reflective of increased water intake observed in the treated rats. They were not considered biologically significant or indicative of an effect of cis-1,2-DCE exposure (U.S. EPA, 2010). Similar to cis-1,2-DCE, slight decreases of uncertain biological significance were observed in RBC parameters in one study of rats orally exposed to trans-1,2-DCE (out of several available) and in an oral study of a 50:50 mixture of the 1,2-DCE isomers. Hematological effects, including decreases in RBC, hemoglobin, and clotting time of blood were observed for the TCE and vinyl chloride by the oral route.

No changes in RBC parameters were observed for any candidate analogue by inhalation exposure.

#### Immunological Effects (Including White Blood Cell [WBC] Parameters)

No inhalation studies evaluating the potential for cis-1,2-DCE to cause immunological effects are available. In an oral study in which female rats were administered cis-1,2-DCE for 90 days, no significant changes in WBC parameters were observed; however, significantly increased absolute and relative thymus weights (by 13 and 17%, respectively) were observed in females at the highest dose (872 mg/kg-day). Decreases in thymus weights were observed in female animals orally dosed with the trans isomer at concentrations ≥224 mg/kg-day (U.S. EPA, 2020). The chronic RfD for trans-1,2-DCE is immune-related, based on suppression of spleen cell antibody production against sheep red blood cells (sRBCs) in mice (U.S. EPA, 2010). Evidence of immunosuppression and immunotoxicity, including decreases in humoral immunity, increased T-cell hyperactivity, and decreased spleen cellularity is observed following oral exposure to TCE. Limited information is available about immunological effects of other candidate analogues following oral exposure.

No studies are available that evaluate immune functional changes in response to cis-1,2-DCE by any route of exposure. The trans-1,2-DCE screening subchronic and chronic p-RfCs are based on decreased WBC and lymphocyte counts in rats. These changes were not associated with histopathology in immune system organs (thymus, spleen, and bone marrow); the weights of these organs were not measured. Although reductions in lymphocyte counts following exposure to trans-1,2-DCE have been hypothesized to reflect a stress-related increase in glucocorticoid levels, no direct evidence supporting this hypothesis is available. Upon further evaluation, the U.S. EPA concluded that the effect on WBC and lymphocyte counts were related to exposure to trans-1,2-DCE (U.S. EPA, 2020). Pneumonic infiltration and severe fatty degeneration in Kupffer cells following inhalation exposure to trans-1,2-DCE could also be considered immune-related—Kupffer cells are highly phagocytic macrophages known to protect systemic circulation from gastrointestinal bacteria (ATSDR, 1996). In inhalation studies of TCE, mice exhibited significant reductions in spleen weight and serum immunoglobulin G (IgG) levels. Exposed rats had a reduced splenic anti-sRBC IgM response (ATSDR, 2019c). In addition to fetal heart malformations, the intermediate and chronic inhalation MRLs and the chronic RfC value for TCE are based on decreased thymus weights in mice exposed to TCE in drinking water (route-to-route extrapolation). Inhalation exposure to vinyl chloride resulted in increases in spleen weights in multiple species and in spontaneous proliferation/transformation of lymphocytes isolated from the spleens of exposed mice. A decrease in WBC counts was observed at higher exposure levels (ATSDR, 2006). No immune-related effects have been observed for Perc following inhalation exposure, and no long-term inhalation studies on 1,1-DCE evaluating immunotoxicity endpoints were identified.

#### Developmental Effects

No inhalation or oral studies on cis-1,2-DCE that evaluated the potential for developmental effects were identified. Developmental effects, including decreased litter sizes, anophthalmia, and increased collagen content of the skin, were observed following oral exposure to Perc, TCE, and vinyl chloride. Limited information is available about developmental effects following oral exposure to trans-1,2-DCE or 1,1-DCE.

Developmental effects indicative of developmental delay (reduced fetal weights and incomplete or delayed ossification) were reported for every candidate analogue following inhalation exposure, in most cases at exposure levels also causing maternal toxicity. The intermediate and chronic inhalation MRLs and the chronic RfC for TCE were based, in part, on fetal heart malformations in mice exposed to TCE in drinking water (route-to-route extrapolation). Studies in humans offer some support for a potential association between projected TCE exposure via vapor intrusion and cardiac birth defects (ATSDR, 2019c). No laboratory inhalation studies on any candidate analogue, including TCE, reported fetal heart effects.

#### Summary

In summary, limited data (no subchronic- or chronic inhalation studies, and only a single subchronic oral study) are available on cis-1,2-DCE for inhalation toxicity comparisons with the candidate analogues. The sensitive effects of subchronic oral exposure to cis-1,2-DCE were mild increases in liver and kidney weights, with limited accompanying serum chemistry or histopathology changes up to the highest doses tested. The liver and kidney were identified as target organs for the other candidate analogues following inhalation exposure, generally showing a variety of lesions and related changes in addition to increases in organ weights. Other potentially relevant endpoints identified for candidate analogues following inhalation exposure include upper respiratory lesions (1,1-DCE, Perc), neurological effects (Perc, TCE), immunological effects (trans-1,2-DCE, TCE), and developmental effects (all candidates).

### Weight-of-Evidence Approach

A tiered weight-of-evidence (WOE) approach as described in Wang et al. (2012) was used to select the overall best analogue chemical. The approach focuses on identifying a preferred candidate for three types of analogues: structural analogues, toxicokinetic or metabolic analogues, and toxicity-like analogues. Selection of the overall best analogue chemical is then based on all of the information from the three analogue types, and the following considerations used in a WOE approach: (1) lines of evidence from U.S. EPA assessments are preferred; (2) biological and toxicokinetic data are preferred over the structural similarity comparisons; (3) lines of evidence that indicate pertinence to humans are preferred; (4) chronic studies are preferred over subchronic studies when selecting an analogue for a chronic value; (5) chemicals with more conservative/health-protective toxicity values may be favored; and (6) if there are no clear indications as to the best analogue chemical based on the other considerations, then the candidate analogue with the most structural similarity may be preferred.

Fifteen unique analogues were identified as part of this assessment: six structural analogues, eight metabolism-related analogues, and one compound identified on the basis of both structural and metabolic similarities (trans-1,2-DCE). Of the candidate analogues, trans-1,2-DCE is the most appropriate structural and metabolic analogue for cis-1,2-DCE, with the same shared structural features (i.e., an alkene and two vinylic chlorine atoms), shared structural alerts, similar physicochemical properties, and common metabolic pathways (i.e., CYP450-mediated metabolism resulting in an unstable epoxide intermediate that rearranges to form 2,2-dichloroacetaldehyde, which is then enzymatically converted to 2,2-dichloroethanol and DCA with little downstream GSH conjugation). That quantitative differences exist between the 1,2-DCE isomers in uptake, overall rate of metabolism, and relative amounts of unique metabolites produced is acknowledged, although data were not located to inform the impact of these toxicokinetic differences on toxicological potency or effect. Major toxicokinetic differences, including longer clearance times, GSH conjugation pathways that yield reactive metabolites, and primary elimination route of exhalation, suggest that Perc and TCE are less suitable analogues for cis-1,2-DCE.

Limitations in the toxicity data available for cis-1,2-DCE, including lack of inhalation data, pose challenges for evaluating analogues on the basis of toxicodynamic comparisons. Target organs/systems identified from oral studies with cis-1,2-DCE are the liver and kidney (organ weight increases with limited serum chemistry or histopathological changes), and the derivation of the chronic and subchronic RfD values was based on kidney effects. Although the relevance of directly comparing oral and inhalation data is uncertain, the liver and/or kidney were also identified as relevant target organs for all of the analogues following inhalation exposure. Other relevant toxicity targets of inhalation exposure shared among the analogues include upper respiratory lesions (1,1-DCE, Perc), neurological effects (Perc, TCE), immunological effects (trans-1,2-DCE, TCE), and developmental effects (all candidates). Although toxicity comparisons revealed commonality among oral exposure to cis-1,2-DCE and inhalation exposure to candidate analogues, several notable differences were also apparent. Both Perc and TCE have an oxidation-independent GSH conjugation pathway, not observed in cis-1,2-DCE metabolism, that produces reactive metabolites thought to contribute to liver and kidney toxicity. In addition, the neurotoxic effects of Perc are thought to be due to the parent compound rather than to any metabolites shared with cis-1,2-DCE. Similarly, the TCE neurotoxic effects are thought to be mediated partially by the nonshared metabolite, chloral hydrate. Based on major differences in both toxicodynamics and toxicokinetics, Perc and TCE are not suitable analogues for cis-1,2-DCE and were not considered further.

From the remaining candidates (trans-1,2-DCE, 1,1-DCE, and vinyl chloride), trans-1,2-DCE is selected as the source analogue for the derivation of inhalation toxicity values primarily on the basis of structural and metabolic considerations, with some support from limited oral toxicity data comparisons. Table A-7 presents oral toxicity values and data for cis- and trans-1,2-DCE. cis-1,2-DCE and trans-1,2-DCE elicited similar, mild effects on the liver and kidney after subchronic oral exposure (organ weight increases with limited serum chemistry and histopathological changes). Differences in RfD values point to potential differences in potency, which could be related to the differences in uptake and metabolism described above. Still, the subchronic point of departure (POD) for trans-1,2-DCE is only ∼threefold higher than the subchronic POD for cis-1,2-DCE, and critical effects (mild liver and kidney effects) were similar across isomers. Subchronic human equivalent dose (HED) PODs for the two isomers are within twofold of each other. For chronic PODs, the potency difference is more pronounced (the POD is ∼13-fold higher and HED POD is ∼7-fold higher for trans-1,2-DCE compared with cis-1,2-DCE) and the critical effects are different (immunotoxicity for trans-1,2-DCE and increased kidney weight for cis-1,2-DCE).

Table A-7 Comparison of Subchronic and Chronic Oral Toxicity Values and Effects on Target Organs/Systems Following Oral Exposure to cis-1,2-DCE and trans-1,2-DCE^a^

Chemical | cis-1,2-DCE | trans-1,2-DCE
Repeat-dose toxicity—subchronic
POD (mg/kg-d); [HED POD (mg/kg-d)]^b^ | 5.1; (1.3) | 17; (2.4)
POD type | BMDL10 | NOAEL
Intermediate UFC | 300 (UF_A_ = 10; UF_H_ = 10; UF_D_ = 3) | 100 (UF_A_ = 10; UF_H_ = 10)
Subchronic RfD/p-RfDs or intermediate MRL (mg/kg-d) | 2 × 10^−2^ | 2 × 10^−1^
Critical effects | Increased relative kidney weight | Increased serum ALP
Species | Rat | Mouse
Duration | 90 d | 90 d
Route (method) | Oral (gavage) | Oral (drinking water)
Source | U.S. EPA (2011c) | ATSDR (1996)
Repeat-dose toxicity—chronic
POD (mg/kg-d) | 5.1; (1.3) | 65; (9.1)
POD type | BMDL10 | BMDL1SD
Chronic UFC | 3,000 (UF_A_ = 10; UF_H_ = 10; UF_D_ = 3; UF_S_ = 10) | 3,000 (UF_A_ = 10; UF_H_ = 10; UF_D_ = 3; UF_S_ = 10)
Chronic RfD/p-RfD (mg/kg-d) | 2 × 10^−3^ | 2 × 10^−2^
Critical effects | Increased relative kidney weight | Suppression of the humoral immune system (decreased spleen antibody production against sRBCs)
Species | Rat | Mouse
Duration | 90 d | 90 d
Route (method) | Oral (gavage) | Oral (drinking water)
Source | U.S. EPA (2010) | U.S. EPA (2010)
Effects on target organs/systems in subchronic and chronic studies
Target organ/system | Effect (species) ^b^ ^,^ ^c^ ^,^ ^d^
Liver | ≥97 mg/kg-d ↑ relative liver weight, ↑ absolute liver weight; 90 d (rat); Doses up to 872 mg/kg-d tested: no changes in AST or histopathology | ≥175 mg/kg-d ↑ serum ALP; ↑ relative liver weight; 90 d (mouse, rat); Observations at higher doses: ↑ absolute and relative liver weight; No clinical chemistry changes in other studies up to 3,760 mg/kg-d. No histopathology.
Kidney | ≥32 mg/kg-d ↑ relative kidney weight; 90 d (rat); Doses up to 872 mg/kg-d tested: No adverse clinical chemistry changes or histopathology. | ≥1,257 mg/kg-d ↑ absolute kidney weight and kidney:brain weight ratio, nonsignificant increase in kidney:body weight ratio; 90 d (rat, mouse); No clinical chemistry or histopathology at higher doses.
Respiratory | No clinical signs or lung histopathology up to 872 mg/kg-d (lung weight not measured); 90 d (rat) | 452 mg/kg-d ↓ lung weight; 90 d (mouse); No histopathology at higher doses.
Neurological | No clinical signs or changes in brain weight or histopathology up to 872 mg/kg-d; 90 d (rat) | No clinical signs, changes in brain weight or histopathology up to 3,245 mg/kg-d (rat) or 8,065 mg/kg-d (mouse); 14 wk
Hematological (red cell) | ≥97 mg/kg-d ↓ hematocrit; 90 d (rat); Doses up to 872 mg/kg-d tested: ↓ hemoglobin and RBC count; Observed changes were small and not biologically significant. | ≥380 mg/kg-d ↓ RBC counts; 90 d (rat, mouse)
Immunological | 872 mg/kg-d (highest dose) ↑ relative thymus weight in females; 90 d (rat); No changes in relative spleen weight. No histopathology in spleen or thymus. | ≥175 mg/kg-d Significant decrease in sRBC-responsive cells; 90 d (mouse); Observations at higher doses: ↓ absolute and relative thymus weight; No histopathology at highest dose.
Developmental | ND | ND

a U.S. EPA-derived toxicity values are reported. In instances where no U.S. EPA toxicity value is available, ATSDR MRL values are shown.

b HED PODs were calculated using: HED POD = POD × (BW_A_/BW_H_)^1/4^. Reference body weights were taken from U.S. EPA (1988). Because data for CD-1 mice were not available, a reference body weight for the average (based on BAF1 and B6C3F1) mouse was used in the HED POD calculations for trans-1,2-DCE.

c The lowest LOAELs or highest NOAELs for effects on the target organ/system are shown; ≥ indicates that other effects were reported at doses greater than or equal to the lowest LOAEL. Selected effects observed at higher doses are listed.

d Species for which effects in the target organ/system were observed are shown in parentheses. The lowest LOAEL was observed in the first species listed.

↑ = increased; ↓ = decreased; ALP = alkaline phosphatase; AST = aspartate aminotransferase; ATSDR = Agency for Toxic Substances and Disease Registry; BMDL = benchmark dose lower confidence limit; BMDL10 = 10% benchmark dose lower confidence limit; BW_A_ = animal body weight; BW_H_ = human body weight; cis-1,2-DCE = cis-1,2-dichloroethylene; HED = human equivalent dose; LOAEL = lowest-observed-adverse-effect level; MRL = minimal risk level; ND = not determined; NOAEL = no-observed-adverse-effect level; p-RfD = provisional reference dose; POD = point of departure; RBC = red blood cell; RfD = reference dose; SD = standard deviation; sRBC = sheep red blood cell; trans-1,2-DCE = trans-1,2-dichloroethylene; UF_A_ = interspecies uncertainty factor; UFC = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor; U.S. EPA = U.S. Environmental Protection Agency.

Although the liver and kidney were determined to be targets of toxicity of both cis- and trans-1,2-DCE, immunological effects were determined to be a more sensitive endpoint for trans-1,2-DCE and are used as the critical effect in deriving its screening p-RfC value. Immune-related responses were observed for trans-1,2-DCE by oral and inhalation exposure. Limited data are available to evaluate potential immune-related effects caused by cis-1,2-DCE by either oral or inhalation exposure. However, relative thymus weights increased in female rats orally exposed to cis-1,2-DCE for 90 days. The direction of effect was opposite in mice orally exposed to trans-1,2-DCE, which showed decreased absolute and relative thymus weights after 90 days. Of note is that organ-weight changes are not the most sensitive effects for detecting immunotoxicity. Thus, immunotoxicity cannot be ruled out for cis-1,2-DCE as a potential target organ effect because immune functional measures have not been evaluated via either oral or inhalation routes of exposure for this chemical.

Differences in oral POD values for cis- and trans-1,2-DCE described above potentially imply that the RfC values for trans-1,2-DCE might not be adequately protective for inhalation exposure to cis-1,2-DCE. However, an examination of measured rat and human blood-gas partition coefficients for the two isomers reveals subtle differences that ultimately enhance confidence in this case the screening p-RfC values for trans-1,2-DCE are likely to be protective for any effects from cis-1,2-DCE. On the basis of guidelines described in U.S. EPA (1994), human equivalent concentrations (HECs) for systemic effects from a Category 3 gas (i.e., a gas that has its effects outside the respiratory tract, such as cis-1,2-DCE and trans-1,2-DCE) are calculated by multiplying the critical concentration in the animal study by the ratio of blood-gas partition coefficients for the chemical (animal/human), with the stipulation that a value of 1 is used if the animal value exceeds the human value. For trans-1,2-DCE, the rat value (9.58) is greater than the human value (5.8−6.08), so the default coefficient of 1 was used in the calculation, rather than the calculated value of ∼1.6. This means that the HEC used as the POD for derivation of the screening p-RfCs for trans-1,2-DCE is lower, and therefore more protective, than it would have been based strictly on the ratio of partition coefficients (∼60% of what it would have been). For cis-1,2-DCE, the rat and human blood-gas partition coefficients are 21.6 and 9.2-9.85, for a ratio of ∼2.2. Because the ratio of coefficients is larger for cis-1,2-DCE than for trans-1,2-DCE, use of the default ratio of 1 in the derivation of the screening RfC is even more protective for this isomer (an HEC calculated for this isomer would be ∼45% of the value it would be based strictly on the ratio of partition coefficients). Also of note is that the screening chronic p-RfC for trans-1,2-DCE is lower than the RfC values of all other candidate analogues except TCE, which was determined a less appropriate analogue due to significant toxicokinetic and toxicodynamic differences. Thus, use of the screening inhalation toxicity values for trans-1,2-DCE can reasonably be expected to be protective for cis-1,2-DCE toxicity within the rough order of magnitude margin of error associated with screening toxicity values.

## INHALATION NONCANCER TOXICITY VALUES

### Derivation of a Screening Subchronic Provisional Reference Concentration

On the basis of the overall analogue approach presented in this PPRTV assessment, trans-1,2-DCE was selected as the most appropriate analogue for cis-1,2-DCE for deriving screening subchronic and chronic p-RfCs. The study used for the U.S. EPA screening subchronic and chronic p-RfC values for cis-1,2-DCE is a 90-day inhalation study of trans-1,2-DCE in rats (Kelly 1998 as cited in U.S. EPA, 2020). The PPRTV assessment for trans-1,2-DCE (U.S. EPA, 2020) provided the following study summary:

The toxicity of trans-1,2-DCE (99.86% purity) was evaluated in groups of DCrl:CD (SD) BR rats (15 males and 15 females/group) in an unpublished study following OECD Guideline No. 413 (Kelly, 1998) and complying with Quality Assurance and Good Laboratory Practice (GLP) standards. Rats (approximately 7 weeks old) were exposed, whole body, to analytical concentrations (mean ± standard error [SE], reported by the study author to two significant figures) of 0, 200 ± 0.48, 1,000 ± 1.3, or 4,000 ± 4.7 ppm of trans-1,2-DCE vapor 6 hours/day, 5 days/week, for 90 days (these concentrations correspond to 0, 790, 4,000, and 16,000 mg/m^3^, maintaining the stated significant figures). Ten rats/sex/group were designated for toxicological evaluations and the remaining five rats/sex/group were designated for cell proliferation evaluations. Clinical signs were observed during exposure and immediately after the rats were returned to their cages. Alerting response to an auditory stimulus was checked approximately every 2 hours during each exposure and immediately after. Body weights and food consumption were measured in all animals weekly.

In the toxicology evaluation group, blood samples were collected for hematology and serum chemistry measurements on approximate Test Days 45 and 90 from 10 male and 10 female rats from each exposure group. Urinalysis was performed on the same rats on the same day as the blood draw. One day after the final exposure, 10 rats per sex/exposure concentration were sacrificed for pathological evaluations; the remaining rats (∼5 rats/sex/exposure concentration) were allowed to recover for approximately 1 month prior to sacrifice. Gross examinations were done at necropsy; liver, kidneys, lungs, testes, ovaries, adrenal glands, and brain were weighed, and samples from >45 tissues from 10 males and 10 females from the control and high-exposure groups were fixed in formalin or Bouin’s solution, embedded in paraffin, stained with H & E, and examined microscopically. For low- and mid-exposure groups, the nose, pharynx/larynx, lungs, liver, kidneys, heart, and reproductive organs were microscopically examined. No histopathology was done on recovery animals owing to the lack of treatment-related lesions in the nonrecovery, high-exposure group. Ophthalmological evaluations were done on all rats in the toxicological group at the start of the study and at the end of the exposure period.

In the cell proliferation group, five rats/sex/exposure concentration were sacrificed after approximately 7 and 90 days of exposure for hepatic cell proliferation evaluations. Three days prior to each sacrifice, osmotic pumps filled with 20 mg/mL 5-bromo-2′-deoxyuridine (BrdU) were implanted subcutaneously in designated rats. At sacrifice, the liver and duodenum were collected and processed for immunohistochemical analysis of BrdU incorporation into deoxyribonucleic acid (DNA). Hepatic labeling indices were evaluated only for the control and high-exposure groups.

Statistical analyses of the data performed by the study author included analysis of variance (ANOVA), Dunnett’s test for multiple pairwise comparisons, Bartlett’s test for homogeneity, Cochran-Armitage test for trend, and when results of Bartlett’s test were significant, Kruskal-Wallis and Mann-Whitney U tests. One-way ANOVA tests for linear trend were conducted for the purposes of this assessment using GraphPad Prism software (Version 8.4.2) to evaluate potential treatment-related hematological changes (i.e., WBC and lymphocyte counts) (GraphPad, 2018).

One death (a female in the 4,000-mg/m^3^ cell proliferation group) was reported; the animal was sacrificed on Test Day 85 due to an ulcer/erosion of the skin on the tail. There were significant increases in incidences of stained or wet perineum in female rats in the 4,000- and 16,000-mg/m^3^ toxicology evaluation groups, but the effects were described as transient and likely related to the stresses of exposure. No other clinical signs or significant differences in mean body weights, body-weight gains, or food consumption between the control and exposed were observed. Minor ophthalmologic lesions were determined to be incidental and not compound related.

Hematology and clinical chemistry examinations revealed statistically significant changes in some parameters, including hemoglobin (Hb), hematocrit (Hct), white blood cell (WBC), lymphocytes, monocytes, alkaline phosphatase (ALP), aspartate aminotransferase (AST), sorbitol dehydrogenase (SDH), albumin, and glucose (see Tables B-3 and B-4). The study author discounted these changes because they either did not increase (or decrease) consistently with increasing exposure concentration, appeared to be transient (observed at 45 days but not 90 days) and/or were small in magnitude compared with historical controls. However, the alterations in WBC and lymphocyte counts appeared to be treatment related. Decreased WBC and lymphocyte counts were observed in exposed animals, reaching statistical significance in males at the highest exposure concentration (16,000 mg/m^3^) after the 45-day (WBC and lymphocyte counts) and 90-day (lymphocyte counts only) sampling time points. The toxicological significance of the WBC and lymphocyte responses were further questioned by the study author, arguing that the observed changes were small compared with historical controls but provided no further details. Kelly (1998) also indicated that leukopenia (low WBC count and differentials) could be due to a secondary stress response related to elevation of endogenous glucocorticoids, a phenomenon that has been associated with exposure to irritants in inhalation toxicity studies (Brondeau et al., 1990). However, the cause of the stress was not identified, and there is no direct evidence to support the hypothesis of glucocorticoid-dependent leukopenia following trans-1,2-DCE exposure. The effects on WBC and lymphocytes were generally concentration-related and of similar magnitude across sexes at the 16,000-mg/m^3^ dose group (decreases of 18−20 and 22−26% compared with controls for WBC and lymphocytes, respectively). Statistical analysis performed by the U.S. EPA for the purposes of this assessment provided further evidence in support of the biological significance of the hematological findings, revealing a significant decreased trend in WBC and lymphocyte counts in males at 45 and 90 days and in WBC counts at 45 days, and lymphocyte counts at 90 days in females. As such, U.S. EPA considers these effects to be related to exposure to trans-1,2-DCE. No significant urinalysis findings were identified.

There were no statistically significant organ-weight changes in either sex, and absolute and relative liver and kidney weights were within 10% of control values in all groups (see Table B-5). Incidence data reported in the study showed no significant gross or microscopic lesions in any tissues that were attributable to trans-1,2-DCE exposure.

In the cell proliferation group, no differences in the hepatic labeling indices were observed between the control and 16,000-mg/m^3^ rats of either sex (lower exposure groups were not evaluated).

A no-observed-adverse-effect level (NOAEL) of 4,000 mg/m^3^ and lowest-observed-adverse-effect level (LOAEL) of 16,000 mg/m^3^ were identified from this study on the basis of statistically significant decreases in WBCs and lymphocytes at 45 days and decreased WBC counts at 90 days in male rats exposed to trans-1,2-DCE vapors for up to 90 days under the study conditions described (U.S. EPA, 2020). Also noted was that trend tests supported concentration-related decreases in WBC and lymphocyte counts in both sexes. The reported study concentrations of 0, 790, 4,000, and 16,000 mg/m^3^ were converted to corresponding HEC_ER_ (human equivalent concentration for extrarespiratory effects) values of 0, 140, 710, and 2,800 mg/m^3^, respectively, by U.S. EPA (2020). The 90-day WBC and lymphocyte count data for both males and females for these endpoints were evaluated via benchmark dose (BMD) modeling.

The benchmark concentration lower confidence limit 1 standard deviation (BMCL_1SD_) human equivalent concentration (HEC) of 109 mg/m^3^ for decreased lymphocyte counts in male rats was identified as the most sensitive point of departure (POD) for deriving screening-level p-RfC values for trans-1,2-DCE.

The screening subchronic p-RfC for trans-1,2-DCE was derived from the BMCL_1SD_ of 109 mg/m^3^ by applying a composite uncertainty factor (UF_C_) of 300 (reflecting an interspecies uncertainty factor [UF_A_] of 3, an intraspecies uncertainty factor [UF_H_] of 10, and a database uncertainty factor [UF_D_] of 10) to the selected POD of 109 mg/m^3^ (U.S. EPA, 2020). Wang et al. (2012) indicated that the uncertainty factors typically applied in deriving a toxicity value for the chemical of concern are the same as those applied to the analogue unless additional information is available.

Screening Subchronic p-RfC = Analogue POD ÷ UF_C_ = 109 mg / m^3^ ÷ 300 = 4 × 10^− 1^ mg / m^3^

Table A-8 summarizes the UFs for the screening subchronic p-RfC for cis-1,2-DCE.

Table A-8 Uncertainty Factors for the Screening Subchronic p-RfC for cis-1,2-DCE (CASRN 156-59-2)

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^) is applied to account for uncertainty associated with extrapolating from animals to humans, using toxicokinetic cross-species dosimetric adjustment for extrarespiratory effects from a Category 3 gas, as specified in U.S. EPA (1994) guidelines for deriving p-RfCs.
UF_H_ | 10 | A UF_H_ of 10 is applied to account for human variability in susceptibility, in the absence of information to assess toxicokinetic and toxicodynamic variability in humans.
UF_D_ | 10 | A UF_D_ of 10 is applied to account for deficiencies and uncertainties in the trans-1,2-DCE analogue database and absence of toxicity data for cis-1,2-DCE.
UF_L_ | 1 | A UF_L_ of 1 is applied because the POD is a BMCL.
UF_S_ | 1 | A UF_S_ of 1 is applied because the POD for the subchronic p-RfC was derived from subchronic data.
UF_C_ | 300 | Composite UF = UF_A_ × UF_H_ × UF_D_ × UF_L_ × UF_S_.

BMCL = benchmark concentration lower confidence limit; cis-1,2-DCE = cis-1,2-dichloroethylene; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; POD = point of departure; p-RfC = provisional reference concentration; trans-1,2-DCE = trans-1,2-dichloroethylene; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

### Derivation of a Screening Chronic Provisional Reference Concentration

trans-1,2-DCE was also selected as the analogue for cis-1,2-DCE for derivation of a screening chronic p-RfC. The key study and calculation of the POD were described above for the subchronic p-RfC. The screening chronic p-RfC for trans-1,2-DCE was derived by applying a UFC of 3,000 (UF_A_ = 3, UF_H_ = 10, UF_D_ = 10, and a subchronic-to-chronic extrapolation uncertainty factor [UF_S_] of 10 for use of a subchronic BMCL as a POD) to the selected POD of 109 mg/m^3^. In deriving the screening chronic p-RfC for cis-1,2-DCE, the same uncertainty factors were used.

Screening Chronic p-RfC = Analogue POD ÷ UF_C_ = 109 mg / m^3^ ÷ 3,000 = 4 × 10^− 2^ mg / m^3^

Table A-9 summarizes the uncertainty factors for the screening chronic p-RfC for cis-1,2-DCE.

Table A-9 Uncertainty Factors for the Screening Chronic p-RfC for cis-1,2-DCE (CASRN 156-59-2)

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^) is applied to account for uncertainty associated with extrapolating from animals to humans, using toxicokinetic cross-species dosimetric adjustment for extrarespiratory effects from a Category 3 gas, as specified in U.S. EPA (1994) guidelines for deriving p-RfCs.
UF_H_ | 10 | A UF_H_ of 10 is applied to account for human variability in susceptibility, in the absence of information to assess toxicokinetic and toxicodynamic variability in humans.
UF_D_ | 10 | A UF_D_ of 10 is applied to account for deficiencies and uncertainties in the trans-1,2-DCE analogue database and absence of toxicity data for cis-1,2-DCE.
UF_L_ | 1 | A UF_L_ of 1 has been applied for LOAEL-to-NOAEL extrapolation because the POD is a BMCL.
UF_S_ | 10 | A UF_S_ of 10 is applied because the POD for the chronic p-RfC was derived from subchronic data.
UF_C_ | 3,000 | Composite UF = UF_A_ × UF_H_ × UF_D_ × UF_L_ × UF_S_.

BMCL = benchmark concentration lower confidence limit; cis-1,2-DCE = cis-1,2-dichloroethylene; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; POD = point of departure; p-RfC = provisional reference concentration; trans-1,2-DCE = trans-1,2-dichloroethylene; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.