# AUTHORS, CONTRIBUTORS, AND REVIEWERS

## CHEMICAL MANAGER

- Q. Jay Zhao, PhD
  Center for Public Health and Environmental Assessment, Cincinnati, OH

## CONTRIBUTORS

- Robert Mitkus, PhD, DABT
  Center for Public Health and Environmental Assessment, Research Triangle Park, NC
- James A. Weaver, PhD, DABT
  Center for Public Health and Environmental Assessment, Research Triangle Park, NC

## DRAFT DOCUMENT PREPARED BY

- SRC, Inc.
  7502 Round Pond Road
  North Syracuse, NY 13212

## PRIMARY INTERNAL REVIEWERS

- Daniel D. Petersen, MS, PhD, DABT, ATS, ERT
  National Center for Environmental Assessment, Cincinnati, OH
- Ingrid L. Druwe, PhD
  National Center for Environmental Assessment, Research Triangle Park, NC

## PRIMARY EXTERNAL REVIEWERS

- Eastern Research Group, Inc.
  110 Hartwell Avenue
  Lexington, MA 02421-3136

## PPRTV PROGRAM MANAGEMENT

- Teresa L. Shannon
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- J. Phillip Kaiser, PhD, DABT
  Center for Public Health and Environmental Assessment, Cincinnati, OH

Questions regarding the content of this PPRTV assessment should be directed to the U.S. EPA Office of Research and Development (ORD) Center for Public Health and Environmental Assessment (CPHEA) website at https://ecomments.epa.gov/pprtv.