# 3 DERIVATION OF PROVISIONAL VALUES

## 3.1 DERIVATION OF PROVISIONAL REFERENCE DOSES

The database of oral toxicity studies in animals exposed to calcium phosphate salts is limited to a 28-day repeated-dose toxicity study and an R/D screening test of DCP [NIER (2010, 2009) as cited in OECD (2011a)], a combined short-term, repeated-dose with R/D toxicity study of TCP [NIER (2007) as cited in OECD (2012)], developmental toxicity studies of MCP monohydrate in rats, mice, and rabbits (FDRL, 1974), and a developmental toxicity study of a TCP food additive in rats (Güngörmüş et al., 2010). With exception of the latter study (Güngörmüş et al., 2010), these studies were unpublished and/or only available as reported in secondary sources (OECD, 2012, 2011a).

The study by Güngörmüş et al. (2010) is inadequate for deriving a provisional reference dose (p-RfD). The study identified increased transumbilical diameter and unilateral reductions in bone size as treatment-related effects; however, the study was confounded by several limitations. The study tested a TCP food additive that also contained significant microbiological and heavy metal contamination. In addition, the number of animals used per group was low (5/group), and only one dose level was used. Because it was not possible to determine whether observed effects were due to TCP exposure or other contaminants, effect levels were not identified for this study.

FDRL (1974) reported developmental toxicity studies of MCP monohydrate in rats, mice, and rabbits; however, this was an unpublished report containing appendices with minimal study details and some data tables (no measure of variation was provided, and no statistical analyses were performed). The studies by NIER (2007) as cited in OECD (2012) and NIER (2009, 2010) as cited in OECD (2011a) were conducted according to OECD guidelines and evaluated numerous systemic, reproductive, and developmental endpoints; however these studies were not published and are available only as reported in secondary sources. Given the limitations in the available studies for calcium phosphate salts, they were not considered suitable for deriving a p-RfD. However, the studies appear to provide sufficient data to develop a screening-level subchronic p-RfD value for calcium phosphate salts (see Appendix A).

## 3.2 DERIVATION OF PROVISIONAL REFERENCE CONCENTRATIONS

Human and animal data are inadequate to derive subchronic or chronic provisional reference concentrations (p-RfCs) for calcium phosphate salts. No repeated-exposure inhalation data for calcium phosphate salts have been identified.

## 3.3 SUMMARY OF NONCANCER PROVISIONAL REFERENCE VALUES

Table 5 presents a summary of noncancer provisional reference values.

Table 5 Summary of Noncancer Reference Values for Calcium Phosphate Salts (Multiple CASRNs)

Toxicity Type (units) | Species/Sex | Critical Effect | p-Reference Value | POD Method | POD (HED/HEC) | UF_C_ | Principal Study
Screening subchronic p-RfD (mg/kg-d) for calcium phosphate salts | Rat/both | No treatmentrelated effects | 8 × 10^0^ | NOAEL | 240 | 30 | NIER (2007) as cited in OECD (2012); NIER (2009, 2010) as cited in OECD (2011a)
Chronic p-RfD (mg/kg-d) | NDr
Subchronic p-RfC (mg/m^3^) | NDr
Chronic p-RfC (mg/m^3^) | NDr

HEC = human equivalent concentration; HED = human equivalent dose; NDr = not determined; NOAEL = no-observed-adverse-effect level; POD = point of departure; p-RfC = provisional reference concentration; p-RfD = provisional reference dose; UF_C_ = composite uncertainty factor.

## 3.4 CANCER WEIGHT-OF-EVIDENCE DESCRIPTOR

Table 6 identifies the cancer weight-of-evidence (WOE) descriptor for calcium phosphate salts. No human or animal studies evaluating cancer endpoints are available for any of the chemicals. Limited in vitro genotoxicity assays, available only in secondary sources (see Table 4A), have reported negative results. Under the U.S. EPA (2005) cancer guidelines, the available data are inadequate for an assessment of human carcinogenic potential, and the cancer WOE descriptor for calcium phosphate salts is “Inadequate Information to Assess Carcinogenic Potential” for both the oral and inhalation routes of exposure.

Table 6 Cancer WOE Descriptor for Calcium Phosphate Salts (Multiple CASRNs)

Possible WOE Descriptor | Designation | Route of Entry (oral, inhalation, or both) | Comments
“Carcinogenic to Humans” | NS | NA | There are no human carcinogenicity data identified to support this descriptor.
“Likely to Be Carcinogenic to Humans” | NS | NA | There are no animal carcinogenicity studies identified to support this descriptor.
“Suggestive Evidence of Carcinogenic Potential” | NS | NA | There are no animal carcinogenicity studies identified to support this descriptor.
“Inadequate Information to Assess Carcinogenic Potential” | Selected | Both | This descriptor is selected due to the lack of any information on carcinogenicity of calcium phosphate salts.
“Not Likely to Be Carcinogenic to Humans” | NS | NA | No evidence of noncarcinogenicity is available.

NA = not applicable; NS = not selected; WOE = weight of evidence.

## 3.5 DERIVATION OF CANCER RISK ESTIMATES

Owing to a lack of carcinogenicity data, derivation of cancer risk estimates is precluded (see Table 7).

Table 7 Summary of Cancer Risk Estimates for Calcium Phosphate Salts (Multiple CASRNs)

Toxicity Type (units) | Species/Sex | Tumor Type | Cancer Risk Estimate | Principal Study
p-OSF (mg/kg-d)^−1^ | NDr
p-IUR (mg/m^3^)^−1^ | NDr

NDr = not determined; p-IUR = provisional inhalation unit risk; p-OSF = provisional oral slope factor.