# 1 INTRODUCTION

Phosphorus is most commonly found in nature in its pentavalent form in combination with oxygen, as phosphate (PO_4_^3−^). Phosphorus is an essential constituent of all living organisms, and its content is quite uniform across most plant and animal tissues. Orthophosphate is the basic unit for all phosphates. Condensed phosphates (pyro-, meta-, and other polyphosphates) are formed when two or more orthophosphate molecules condense into a single molecule. Pyrophosphates refer to compounds with two condensed orthophosphates, and higher number polymers are termed polyphosphates, sometimes preceded by a prefix indicating the number (e.g., tri- and tetrapolyphosphates have three and four condensed phosphates, respectively). The term “metaphosphates” is used when phosphoric acid moieties form a cyclic (ring) structure. Inorganic phosphates (both ortho- and condensed phosphate anions) can be grouped into four classes based on their cations: monovalent (sodium, potassium, and hydrogen), divalent (calcium and magnesium), ammonium, and aluminum. The phosphoric acids have been grouped with the other monovalent cations based on valence state.

This document addresses the available data on the toxicity of calcium phosphate salts. Calcium phosphate salts are considered in this document separate from the other inorganic phosphates (sodium, potassium, ammonium, and aluminum phosphates) based on the expectation that the presence of calcium would influence the chemistry, toxicokinetics, and/or toxicity of the phosphate salt relative to the other classes of inorganic phosphates. Calcium phosphates are much less soluble than sodium or potassium phosphates (Gilmour, 2019). In addition, interactions between phosphate and calcium occur both in the intestine (where calcium phosphate formation reduces absorption of both ions) and in the kidney (where phosphate decreases urinary calcium excretion) [as reviewed by EFSA (2015)]. There is evidence that the ratio of calcium:phosphate (Ca:P) is an important determinant of phosphate toxicity; thus, administration of calcium phosphate might be expected to yield different toxicological effects than administration of sodium or potassium phosphate. The reader is referred to the PPRTV documents for sodium, potassium, ammonium, and aluminum phosphates for assessments of those inorganic phosphate salts.

All chemicals in this assessment are inorganic compounds consisting of PO_4_^3−^ with calcium (CASRN 7440-70-2) at different ratios (1:1, 2:1, 1:2, etc.). Calcium, atomic number 20 is a member of the Group 2 alkaline earth metals. Calcium is the fifth most abundant element in the earth’s crust (Vrana, 2011). Calcium is widely distributed in rocks, soils, and water (Vrana, 2011). In the environment and biological systems, calcium is found in complexes and salts (Vrana, 2011).

Calcium phosphates occur naturally and are found in living organisms. They are the main component of bone and teeth (Gilmour, 2019). Calcium phosphates occur as hydrated minerals, most commonly as deposits of apatite (Dorozhkin, 2009). Human exposure to calcium phosphates is expected to be common because they are used as food additives that are generally recognized as safe (GRAS) by the U.S. Food and Drug Administration (FDA, 2020, 2019). The calcium phosphate compounds (monocalcium phosphate [MCP], dicalcium phosphate [DCP], tricalcium phosphate [TCP], calcium pyrophosphate [CPP], and hydroxyapatite) are used in food. CPP is also used in toothpastes as an abrasive (NLM, 2020a, b, c, d, e). MCP is a leavening agent and acidulant in flour and baking soda; DCP and TCP are used as antacids; DCP, TCP, CPP, and hydroxyapatite are all used as dietary supplements for calcium and phosphorus (NLM, 2020a, b, c, d, e). The calcium phosphates are multiple-purpose food substances (182.1217), dietary supplements (182.5217, 182.5223), and nutrients (182.8217, 182.8223) classified by the FDA as GRAS when used in accordance with good manufacturing practice under Chapter 21 of the Code of Federal Regulations (FDA, 2020, 2019). MCP is also classified by the FDA as GRAS as a sequestrant (182.6215) (FDA, 2020).

The empirical formulas for several calcium phosphates are provided in Table 1A. Table 1B provides available information on the physicochemical properties of these compounds. All of the compounds in the table are listed in the U.S. EPA 2019 Toxic Substance and Chemical Act public inventory, with hydroxyapatite listed as Hydroxylapatite (Ca_5_(PO_4_)_3_OH), CASRN 1306-06-5 (U.S. EPA, 2019), and are registered in Europe’s Registration, Evaluation, Authorisation and Restriction of Chemicals (REACH) program (CASRNs 7758-23-8, 7757-93-9, 7758-87-4, 7790-76-3, 1306-06-5, and 12167-74-7) (ECHA, 2019a, b, c, d, e). The Inorganic Phosphates REACH Consortium substance information exchange forum considers CASRNs 1306-06-5 and 12167-74-7 to be the same substance, and many sources cite these two CASRNs for hydroxyapatite interchangeably (NLM, 2020e; Thornton, 2010). Di-, tri-, and tetra-hydrates of many of these chemicals with other CASRNs are also known.

Table 1A Identity and Molecular Weight of Calcium Phosphates^a^

Compound | Synonym | CASRN | Molecular Formula | MW (g/mol) | Physical State
Phosphoric acid, calcium salt (2:1) | MCP, anhydrous | 7758-23-8 | CaH_4_P_2_O_8_ | 234.05 | Colorless pearly scales or powder^b^
Phosphoric acid, calcium salt (1:1) | DCP | 7757-93-9 | CaHPO_4_ | 136.056 | White crystalline powder^b^
Phosphoric acid, calcium salt (2:3) | TCP | 7758-87-4 | Ca_3_P_2_O_8_ | 310.174 | White crystalline powder^b,^ ^c^
Diphosphoric acid, calcium salt (1:2) | CPP | 7790-76-3 | Ca_2_P_2_O_7_ | 254.097 | White crystalline powder^d^
Calcium hydroxide phosphate | Hydroxyapatite | 12167-74-7, 1306-06-5 | Ca_5_HP_3_O_13_ | 502.306 | Solid, crystalline^b^

a U.S. EPA (2020a).

b NLM (2020a), NLM (2020b), NLM (2020c), NLM (2020e).

c ECHA (2010g).

d Schrödter et al. (2012).

CPP = calcium pyrophosphate; DCP = dicalcium phosphate; MCP = monocalcium phosphate; MW = molecular weight; TCP = tricalcium phosphate.

Table 1B Physicochemical Properties of Calcium Phosphates

Compound | CASRN | Melting Point (°C) | Density (g/cm^3^ at 25°C) | pH (unitless) | pKa (unitless) | Solubility in Water
MCP | 7758-23-8 | 200 | 2.220 at 18°C^a^ | NV | NV | Moderate solubility in water;^a^ 93.9 g/L at pH 2.4^b^
DCP | 7757-93-9 | >450^c^ | 2.92^c^ | 6.5^c^ | NV | Sparingly soluble in water;^a^ 153 g/L at pH 6.5^d^
TCP | 7758-87-4 | 1,670^c^ | 3.14^c^ | NV | NV | Low solubility;^c^ ≤20 mg/L at 20°C
CPP | 7790-76-3 | 1,353^e^ | 2.866 at 20°C^f^ | NV | NV | Practically insoluble in water;^e^ <0.255 mg/L at pH 6.3–6.5^f^
Hydroxyapatite | 12167-74-7, 1306-06-5 | 1,110 (decomposes)^a^ | 3.1–3.2^a^ | NV | NV | Practically insoluble in water;^a^ 6.57 mg/L at 20°C and pH 7.2–7.4,^g^ 36.23 mg/L at 20°C based on calcium concentration, pH not reported^h^

a NLM (2020a), NLM (2020b), NLM (2020e).

b ECHA (2010a).

c OECD (2012), OECD (2011b).

d OECD (2011a), ECHA (2010b).

e Schrödter et al. (2012).

f ECHA (2015a), ECHA (2010c).

g ECHA (2010d).

h ECHA (2016).

CPP = calcium pyrophosphate; DCP = dicalcium phosphate; MCP = monocalcium phosphate; NV = not available; TCP = tricalcium phosphate.

Calcium phosphate compounds are more soluble in acidic conditions than buffered neutral or basic solutions. MCP and DCP have water solubility values of 93.9 and 153 g/L in unbuffered water, respectively. The addition of each chemical to the unbuffered water in the solubility test resulted in a final solution of pH 2.4 for MCP and 6.5 for DCP (ECHA, 2010e, f). MCP and DCP dissolve incongruently in water, with variations based on temperature and the amount of water (Gilmour, 2019). The water solubilities of several calcium phosphates are shown in Table 1B.

A summary of available toxicity values for calcium phosphate salts (multiple CASRNs) from U.S. EPA and other agencies/organizations is provided in Table 2.

Table 2 Summary of Available Toxicity Values for Calcium Phosphate Salts (Multiple CASRNs)

Source (parameter)^a,^ ^b^ | Phosphorus and Calcium Phosphates | Value (applicability) | Notes | Reference^c^
Noncancer
IRIS | NA | NV | NA | U.S. EPA (2020b)
HEAST | NA | NV | NA | U.S. EPA (2011)
DWSHA | NA | NV | NA | U.S. EPA (2018)
ATSDR | NA | NV | NA | ATSDR (2020)
EFSA (AI) | P | AI by age:; 7–11 mo: 160 mg/d; 1–3 yr: 250 mg/d; 4–10 yr: 440 mg/d; 11–17 yr: 640 mg/d; Adults and pregnant/lactating women: 550 mg/d | P from all sources. | EFSA (2015)
IOM (UL) | P | Children (1–8 yr): 3,000 mg/d; Adolescents (9–18 yr):; 4,000 mg/d; Adults ≤70 yr: 4,000 mg/d; Adults >70 yr: 3,000 mg/d; Pregnant women: 3,500 mg/d; Lactating women: 4,000 mg/d | The maximum level of daily nutrient intake that is likely to pose no risk of adverse effects. The UL represents total intake from food, water, and supplements. | IOM (1997)
IPCS/WHO (MTDI) | P | 70 mg/kg BW | Maximum intake of P across all sources; based on nephrocalcinosis in rats. | WHO (1982)
CalEPA | NA | NV | NA | CalEPA (2020); CalEPA (2019)
OSHA | NA | NV | NA | OSHA (2020a); OSHA (2020b); OSHA (2020a)
NIOSH | NA | NV | NA | NIOSH (2018)
ACGIH | NA | NV | NA | ACGIH (2019)
USAPHC (air-MEG) | Dicalcium phosphate dihydrate (CASRN 7789-77-7) | 1-h critical: 250 mg/m^3^; 1-h marginal: 50 mg/m^3^; 1-h negligible: 30 mg/m^3^ | Basis: TEELs | U.S. APHC (2013)
USAPHC (air-MEG) | Calcium phosphate; ratio not defined (CASRN 10103-46-5) | 1-h critical: 350 mg/m^3^; 1-h marginal: 35 mg/m^3^; 1-h negligible: 20 mg/m^3^ | Basis: TEELs | U.S. APHC (2013)
Cancer
IRIS | NA | NV | NA | U.S. EPA (2020b)
HEAST | NA | NV | NA | U.S. EPA (2011)
DWSHA | NA | NV | NA | U.S. EPA (2018)
NTP | NA | NV | NA | NTP (2016)
IARC | NA | NV | NA | IARC (2019)
CalEPA | NA | NV | NA | CalEPA (2020); CalEPA (2019)
ACGIH | NA | NV | NA | ACGIH (2019)

a Sources: ACGIH = American Conference of Governmental Industrial Hygienists; ATSDR = Agency for Toxic Substances and Disease Registry; CalEPA = California Environmental Protection Agency; DWSHA = Drinking Water Standards and Health Advisories; EFSA = European Food Safety Authority; HEAST = Health Effects Assessment Summary Tables; IARC = International Agency for Research on Cancer; IOM = Institute of Medicine; IPCS = International Programme on Chemical Safety; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; USAPHC = U.S. Army Public Health Command; WHO = World Health Organization.

b Parameters: AI = adequate intake; MEG = military exposure guideline; MTDI = maximum tolerable daily intake; TEEL = temporary emergency exposure limit; UL = tolerable upper intake level.

c Reference date is the publication date for the database and not the date the source was accessed.

BW = body weight; NA = not applicable; NV = not available; P = phosphorus.

Literature searches were conducted in April 2019 and updated in March 2021 for studies relevant to the derivation of provisional toxicity values for the following calcium phosphate salts: MCP, DCP, TCP, and CPP. Searches were conducted using U.S. EPA’s Health and Environmental Research Online (HERO) database of scientific literature. HERO searches the following databases: PubMed, TOXLINE^1^ (including TSCATS1), and Web of Science. The following resources were searched outside of HERO for health-related values: American Conference of Governmental Industrial Hygienists (ACGIH), Agency for Toxic Substances and Disease Registry (ATSDR), California Environmental Protection Agency (CalEPA), Defense Technical Information Center (DTIC), European Centre for Ecotoxicology and Toxicology of Chemicals (ECETOC), European Chemicals Agency (ECHA), U.S. EPA Chemical Data Access Tool (CDAT), U.S. EPA ChemView, U.S. EPA Integrated Risk Information System (IRIS), U.S. EPA Health Effects Assessment Summary Tables (HEAST), U.S. EPA Office of Water (OW), International Agency for Research on Cancer (IARC), U.S. EPA TSCATS2/TSCATS8e, U.S. EPA High Production Volume (HPV), Chemicals via International Programme on Chemical Safety (IPCS) INCHEM, Japan Existing Chemical Data Base (JECDB), Organisation for Economic Co-operation and Development (OECD) Screening Information Data Sets (SIDS), OECD International Uniform Chemical Information Database (IUCLID), OECD HPV, National Institute for Occupational Safety and Health (NIOSH), National Toxicology Program (NTP), Occupational Safety and Health Administration (OSHA), and World Health Organization (WHO).

1 Note that this version of TOXLINE (https://www.nlm.nih.gov/databases/download/toxlinesubset.html) is no longer updated; therefore, it was not included in the literature search update from March 2021.