# APPENDIX C REFERENCES

ACGIH (American Conference of Governmental Industrial Hygienists). (2019). 2019 TLVs and BEIs: Based on the documentation of the threshold limit values for chemical substances and physical agents & biological exposure indices. Cincinnati, OH.
Allam, O; Bahuaud, D; Taché, S; Naud, N; Corpet, DE; Pierre, FH. (2011). Calcium carbonate suppresses haem toxicity markers without calcium phosphate side effects on colon carcinogenesis. Br J Nutr 105: 384–392. 10.1017/S0007114510003624 21134327
ATSDR (Agency for Toxic Substances and Disease Registry). (2020). Toxic substances portal: Toxicological profiles. Atlanta, GA. https://www.atsdr.cdc.gov/toxprofiledocs/index.html
Behling, AR; Greger, JL. (1988). Mineral metabolism of aging female rats fed various commercially available calcium supplements or yogurt. Pharm Res 5: 501–505. 10.1023/A:1015917307961 3244658
Bonjour, JP; Ammann, P; Chevalley, T; Rizzoli, R. (2001a). Protein intake and bone growth [Review]. Can J Appl Physiol 26: S153–S166. 10.1139/h2001-050 11897891
Bonjour, JP; Carrie, AL; Ferrari, S; Clavien, H; Slosman, D; Theintz, G; Rizzoli, R. (1997). Calcium-enriched foods and bone mass growth in prepubertal girls: A randomized, double-blind, placebo-controlled trial. J Clin Invest 99: 1287–1294. 10.1172/JCI119287 9077538
Bonjour, JP; Chevalley, T; Ammann, P; Slosman, D; Rizzoli, R. (2001b). Gain in bone mineral mass in prepubertal girls 3.5 years after discontinuation of calcium supplementation: A follow-up study. Lancet 358: 1208–1212. 10.1016/S0140-6736(01)06342-5 11675056
Bovee-Oudenhoven, IM; Wissink, ML; Wouters, JT; Van der Meer, R. (1999). Dietary calcium phosphate stimulates intestinal lactobacilli and decreases the severity of a salmonella infection in rats. J Nutr 129: 607–612. 10.1093/jn/129.3.607 10082763
CalEPA (California Environmental Protection Agency). (2019). Consolidated table of OEHHA/ARB approved risk assessment health values (September 19, 2019 ed.). Sacramento, CA: California Air Resources Board. https://www.arb.ca.gov/toxics/healthval/contable.pdf
CalEPA (California Environmental Protection Agency). (2020). OEHHA chemical database. Sacramento, CA: Office of Environmental Health Hazard Assessment. Retrieved from https://oehha.ca.gov/chemicals
Cats, A; Mulder, NH; de Vries, EG; Oremus, ET; Kreumer, WM; Kleibeuker, JH. (1993). Calcium phosphate: An alternative calcium compound for dietary prevention of colon cancer? A study on intestinal and faecal parameters in healthy volunteers. Eur J Cancer Prev 2: 409–415.8401176
Cleghorn, GJ; Tudehope, DI. (1981). Neonatal intestinal obstruction associated with oral calcium supplementation. Aust Paediatr J 17: 298–299.7347220
Dorozhkin, SV. (2009). Calcium orthophosphates in nature, biology and medicine. Materials 2: 399–498. 10.3390/ma2020399
ECHA (European Chemicals Agency). (1970). Calcium hydrogenorthophosphate. Short-term repeated dose toxicity. Oral: 001 Supporting | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/15458/7/6/2
ECHA (European Chemicals Agency). (2002). Diammonium hydrogenorthophosphate. Repeated dose toxicity: oral. 001 Key | Experimental result. https://echa.europa.eu/en/registration-dossier/-/registered-dossier/15555/7/6/2
ECHA (European Chemicals Agency). (2010a). Calcium bis(dihydrogenorthophosphate). Water solubility. 001 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/15399/4/9/?documentUUID=a686a95a-1f00-4862-a4bc-348fe63801c6
ECHA (European Chemicals Agency). (2010b). Calcium hydrogenorthophosphate. Water solubility. 001 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/15458/4/9/?documentUUID=50774b32-8fb1-47f4-8758-15dd5e7475fe
ECHA (European Chemicals Agency). (2010c). Dicalcium pyrophosphate. Water solubility. 001 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/20286/4/9/?documentUUID=4752844f-8b94-48f2-9178-f89b02944cec
ECHA (European Chemicals Agency). (2010d). Pentacalcium hydroxide tris(orthophosphate). Water solubility: 001 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/15208/4/9/?documentUUID=2add17ac-463f-4d68-8053-62e56b30eabb
ECHA (European Chemicals Agency). (2010e). Registration dossier: Calcium bis(dihydrogenorthophosphate). Water solubility: 001 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/15399/4/9/?documentUUID=a686a95a-1f00-4862-a4bc-348fe63801c6
ECHA (European Chemicals Agency). (2010f). Registration dossier: Calcium hydrogenorthophosphate. Water solubility. 001 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/15458/4/9/?documentUUID=50774b32-8fb1-47f4-8758-15dd5e7475fe
ECHA (European Chemicals Agency). (2010g). Tricalcium bis(orthophosphate). Appearance/physical state/colour. 001 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/13654/4/2/?documentUUID=ce9db93b-7305-4da6-9e21-9ef4fca24344
ECHA (European Chemicals Agency). (2015a). Dicalcium pyrophosphate. Density. S-01: Summary. https://echa.europa.eu/registration-dossier/-/registered-dossier/20286/4/5
ECHA (European Chemicals Agency). (2015b). Dicalcium pyrophosphate. Genetic toxicity: In vitro. 001 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/13654/4/2/?documentUUID=ce9db93b-7305-4da6-9e219ef4fca24344
ECHA (European Chemicals Agency). (2015c). Dicalcium pyrophosphate. Genetic toxicity: In vitro. 002 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/20286/7/7/2/?documentUUID=6e3bf4f3-a594-4018-88043178d6df3933 (https://echa.europa.eu/registration-dossier/-/registered-dossier/20286/7/7/2/?documentUUID=6e3bf4f3-a594-4018-8804-3178d6df3933)
ECHA (European Chemicals Agency). (2015d). Dicalcium pyrophosphate. Genetic toxicity: In vitro. 003 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/20286/7/7/2/?documentUUID=931d9048-8e13-4726-8d75d160bb7e3b4e (https://echa.europa.eu/registration-dossier/-/registered-dossier/20286/7/7/2/?documentUUID=931d9048-8e13-4726-8d75-d160bb7e3b4e)
ECHA (European Chemicals Agency). (2016). Hydroxylapatite (Ca5(OH)(PO4)3). Water solubility. https://echa.europa.eu/registration-dossier/-/registered-dossier/20278/4/9
ECHA (European Chemicals Agency). (2019a). Registration dossier: Calcium bis(dihydrogenorthophosphate). https://echa.europa.eu/registration-dossier/-/registereddossier/15399 (https://echa.europa.eu/registration-dossier/-/registered-dossier/15399)
ECHA (European Chemicals Agency). (2019b). Registration dossier: Calcium hydrogenorthophosphate. https://echa.europa.eu/registration-dossier/-/registereddossier/15458 (https://echa.europa.eu/registration-dossier/-/registered-dossier/15458)
ECHA (European Chemicals Agency). (2019c). Registration dossier: Dicalcium pyrophosphate. https://echa.europa.eu/registration-dossier/-/registered-dossier/20286
ECHA (European Chemicals Agency). (2019d). Registration dossier: Hydroxylapatite. https://echa.europa.eu/registration-dossier/-/registered-dossier/20278
ECHA (European Chemicals Agency). (2019e). Registration dossier: Tricalcium bis(orthophosphate). https://echa.europa.eu/registration-dossier/-/registereddossier/13654 (https://echa.europa.eu/registration-dossier/-/registered-dossier/13654)
ECHA (European Chemicals Agency). (2020a). Calcium bis(dihydrogenorthophosphate). Toxicokinetics, metabolism, and distribution. Endpoint summary. https://echa.europa.eu/registration-dossier/-/registered-dossier/15399/7/2/1
ECHA (European Chemicals Agency). (2020b). Calcium hydrogenorthophosphate. Toxicokinetics, metabolism, and distribution. Endpoint summary. https://echa.europa.eu/registration-dossier/-/registered-dossier/15458/7/2/1
ECHA (European Chemicals Agency). (2020c). Dicalcium pyrophosphate. Toxicokinetics, metabolism, and distribution. Endpoint summary. https://echa.europa.eu/registrationdossier/-/registered-dossier/20286/7/2/1 (https://echa.europa.eu/registration-dossier/-/registered-dossier/20286/7/2/1)
ECHA (European Chemicals Agency). (2020d). Tricalcium bis(orthophosphate): toxicokinetics, metabolism, and distribution: endpoint summary. https://echa.europa.eu/registrationdossier/-/registered-dossier/13654/7/2/1 (https://echa.europa.eu/registration-dossier/-/registered-dossier/13654/7/2/1)
EFSA (European Food Safety Authority). (2015). Scientific opinion on dietary reference values for phosphorus. EFSA panel on dietetic products, nutrition and allergies (NDA). EFSA J 13: 1–54.
FDA (U.S. Food and Drug Administration). (2019). Food additive status list. Available online at https://www.fda.gov/food/food-additives-petitions/food-additive-status-list
FDA (U.S. Food and Drug Administration). (2020). Code of federal regulations. Title 21 - Food and drugs. Chapter 1: Parts 170-189. Available online at https://www.govinfo.gov/content/pkg/CFR-2019-title21-vol3/pdf/CFR-2019-title21-vol3-chapI.pdf
FDRL (Food and Drug Research Laboratories Inc.). (1974). Teratologic evaluation of FDA 7181 (monocalcium phosphate; monohydrate) in mice, rats and rabbits. (FDABF-GRAS238). U. S. Food and Drug Administration.
Galloway, SD; Tremblay, MS; Sexsmith, JR; Roberts, CJ. (1996). The effects of acute phosphate supplementation in subjects of different aerobic fitness levels. European Journal of Applied Physiology and Occupational Physiology 72: 224–230.8820890
Gilmour, RB. (2019). Phosphoric acids and phosphates. In Kirk-Othmer encyclopedia of chemical technology. Hoboken, NJ: John Wiley & Sons, Inc. 10.1002/0471238961.1608151907011804.a01.pub3
Govers, MJ; Termont, DS; Van der Meer, R. (1994). Mechanism of the antiproliferative effect of milk mineral and other calcium supplements on colonic epithelium. Cancer Res 54: 95–100.8261469
Green, JH; Booth, C; Bunning, R. (2003). Acute effect of high-calcium milk with or without additional magnesium, or calcium phosphate on parathyroid hormone and biochemical markers of bone resorption. Eur J Clin Nutr 57: 61–68. 10.1038/sj.ejcn.1601501 12548298
Guillemant, J; Guillemant, S. (1991). Effects on calcium and phosphate metabolism and on parathyroid function of acute administration of tricalcium phosphate. Bone 12: 383–386. 10.1016/8756-3282(91)90026-F 1665702
Guillemant, J; Guillemant, S. (1993). Modification by phosphate of PTH-dependent renal cyclic AMP response. Horm Metab Res 25: 234–237. 10.1055/s-2007-1002084 8390394
Güngörmüş, C; Kılıç, A; Akay, MT; Kolankaya, D. (2010). The effects of maternal exposure to food additive E341 (tricalcium phosphate) on foetal development of rats. Environ Toxicol Pharmacol 29: 111–116. 10.1016/j.etap.2009.11.006 21787591
Hodge, HC. (1964). Toxicity studies on phosphates. Food Cosmet Toxicol 2: 147–154.14173237
IARC (International Agency for Research on Cancer). (2019). Agents classified by the IARC monographs. Lyon, France. http://monographs.iarc.fr/ENG/Classification/List_of_Classifications.pdf
IOM (Institute of Medicine). (1997). Dietary reference intakes for calcium, phosphorus, magnesium, vitamin D, and fluoride. Washington, DC: National Academy Press. http://www.nap.edu/catalog.php?record_id=5776
Lapré, JA; De Vries, HT; Van der Meer, R. (1993). Cytotoxicity of fecal water is dependent on the type of dietary fat and is reduced by supplemental calcium phosphate in rats. J Nutr 123: 578–585. 10.1093/jn/123.3.587 8463858
Litton Bionetics. (1975). Mutagenic evaluation of compound FDA 71-81, monocalcium phosphate (pp. 37). Rockville, MD: U.S. Food and Drug Administration.
Litton Bionetics. (1976). Mutagenic evaluation of compound FDA 75-30, 007758-87-4, tricalcium phosphate, NF, FCC. (PB257879). Rockville, MD: U.S. Food and Drug Administration.
Lupton, JR; Chen, XQ; Frølich, W. (1995). Calcium phosphate supplementation results in lower rat fecal bile acid concentrations and a more quiescent colonic cell proliferation pattern than does calcium lactate. Nutr Cancer 23: 221–231. 10.1080/01635589509514376 7644389
McClure, ST; Chang, AR; Selvin, E; Rebholz, CM; Appel, LJ. (2017). Dietary sources of phosphorus among adults in the United States: Results from NHANES 2001-2014. Nutrients 9. 10.3390/nu9020095
NIOSH (National Institute for Occupational Safety and Health). (2018). NIOSH pocket guide to chemical hazards. Index of chemical abstracts service registry numbers (CAS No.). Atlanta, GA. http://www.cdc.gov/niosh/npg/npgdcas.html
NLM (National Library of Medicine). (2020a). PubChem: Calcium biphosphate. CASRN: 7758-23-8. Available online at https://pubchem.ncbi.nlm.nih.gov/compound/24454#source=HSDB
NLM (National Library of Medicine). (2020b). PubChem: Calcium hydrogen phosphate. CASRN: 7757-93-9. Available online at https://pubchem.ncbi.nlm.nih.gov/compound/24441
NLM (National Library of Medicine). (2020c). PubChem: Calcium phosphate. CASRN: 7758-87-4. Available online at https://pubchem.ncbi.nlm.nih.gov/compound/24456
NLM (National Library of Medicine). (2020d). PubChem: Calcium pyrophosphate. CASRN: 7790-76-3. Available online at https://pubchem.ncbi.nlm.nih.gov/compound/24632
NLM (National Library of Medicine). (2020e). PubChem: Hydroxyapatite. CASRN: 1306-06-5. Available online at https://pubchem.ncbi.nlm.nih.gov/compound/Hydroxyapatite
NRC (National Research Council). (1995). Nutrient requirements of laboratory animals (Fourth revised ed.). Washington, DC: The National Academies Press. 10.17226/4758
NTP (National Toxicology Program). (2016). 14th Report on carcinogens. Research Triangle Park, NC. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html
O’Connell, MA; Lindberg, JS; Peller, TP; Cushner, HM; Copley, JB. (1989). Gastrointestinal tolerance of oral calcium supplements. J Clin Pharm 8: 425–427.
OECD (Organisation for Economic Co-operation and Development). (2007). SIDS dossier: CAS No. 7783-28-0. Diammonium phosphate [OECD SIDS]. https://hpvchemicals.oecd.org/UI/handler.axd?id=87572146-b81f-4bc5-9e674427c64b1901 (https://hpvchemicals.oecd.org/UI/handler.axd?id=87572146-b81f-4bc5-9e67-4427c64b1901)
OECD (Organisation for Economic Co-operation and Development). (2011a). SIDS dossier: Calcium hydrogenorthophosphate [OECD SIDS]. https://hpvchemicals.oecd.org/UI/handler.axd?id=a5e5b2ac-6faf-47f3-9e866ab52be8bb2a (https://hpvchemicals.oecd.org/UI/handler.axd?id=a5e5b2ac-6faf-47f3-9e86-6ab52be8bb2a)
OECD (Organisation for Economic Co-operation and Development). (2011b). SIDS initial assessment profile: Calcium hydrogenorthophosphate (Cas No. 7757-93-9) [OECD SIDS]. https://hpvchemicals.oecd.org/UI/handler.axd?id=37dea5fd-4afe-4769-a90ccab3eef9ae4e (https://hpvchemicals.oecd.org/UI/handler.axd?id=37dea5fd-4afe-4769-a90c-cab3eef9ae4e)
OECD (Organisation for Economic Co-operation and Development). (2012). SIDS dossier: Tricalcium phosphate [OECD SIDS]. https://hpvchemicals.oecd.org/UI/handler.axd?id=0c859903-7c15-40b2-80a07f1e217b94fd (https://hpvchemicals.oecd.org/UI/handler.axd?id=0c859903-7c15-40b2-80a0-7f1e217b94fd)
OSHA (Occupational Safety & Health Administration). (2020a). Air contaminants: Occupational safety and health standards for shipyard employment, subpart Z, toxic and hazardous substances. (OSHA Standard 1915.1000). Washington, DC. https://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10286
OSHA (Occupational Safety & Health Administration). (2020b). Safety and health regulations for construction: Occupational health and environmental controls: Gases, vapors, fumes, dusts, and mists: Appendix A. Available online at http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10629
Pak, CY; Avioli, LV. (1988). Factors affecting absorbability of calcium from calcium salts and food [Editorial]. Calcif Tissue Int 43: 55–60. 10.1007/BF02555147 3142667
Paßlack, N; Schmiedchen, B; Raila, J; Schweigert, FJ; Stumpff, F; Kohn, B; Neumann, K; Zentek, J. (2016). Impact of increasing dietary calcium levels on calcium excretion and vitamin D metabolites in the blood of healthy adult cats. PLoS ONE 11: e0149190. 10.1371/journal.pone.0149190 26870965
Pierre, F; Santarelli, R; Taché, S; Guéraud, F; Corpet, DE. (2008). Beef meat promotion of dimethylhydrazine-induced colorectal carcinogenesis biomarkers is suppressed by dietary calcium. Br J Nutr 99: 1000–1006. 10.1017/S0007114507843558 17953789
Reginster, JY; Denis, D; Bartsch, V; Deroisy, R; Zegels, B; Franchimont, P. (1993). Acute biochemical variations induced by four different calcium salts in healthy male volunteers. Osteoporos Int 3: 271–275. 10.1007/BF01623832 8400610
Schrödter, K; Bettermann, G; Staffel, T; Wahl, F; Klein, T; Hofmann, T. (2012). Phosphoric acid and phosphates. In B Elvers (Ed.), Ullmann’s encyclopedia of industrial chemistry (7th ed.). Hoboken, NJ: Wiley-VCH Verlag GmbH & Co.
Schuette, SA; Knowles, JB. (1988). Intestinal absorption of Ca(H2PO4)2 and Ca citrate compared by two methods. Am J Clin Nutr 47: 884–888. 10.1093/ajcn/47.5.884 3364403
Sesink, AL; Termont, DS; Kleibeuker, JH; Van der Meer, R. (2001). Red meat and colon cancer: Dietary haem-induced colonic cytotoxicity and epithelial hyperproliferation are inhibited by calcium. Carcinogenesis 22: 1653–1659. 10.1093/carcin/22.10.1653 11577005
Shangraw, RF. (1986). Factors affecting dissolution and absorption of calcium supplements. Maryland PTA Bulletin 62: P21–P23.
Shires, R; Kessler, GM. (1990). The absorption of tricalcium phosphate and its acute metabolic effects. Calcif Tissue Int 47: 142–144. 10.1007/BF02555978 2171734
Sprong, RC; Hulstein, MF; Van der Meer, R. (2002). Dietary calcium phosphate promotes Listeria monocytogenes colonization and translocation in rats fed diets containing corn oil but not milk fat. J Nutr 132: 1269–1274. 10.1093/jn/132.6.1269 12042445
Stauffer Chem Co (Stauffer Chemical Company). (1992). Initial submission: Acute toxicity test battery for monocalcium phosphate anhydrous with cover letter dated 10/23/1992. (EPA/OTS; Doc #88-920010803).
Thornton, C. (2010). REACH merging of SIEFs for bone ash EC 270-423-5 and hydroxylapatite 215-145-7 pentacalcium hydroxide tris(orthophosphate) 235-330-6. Available online at https://www.inorganic-phosphates.org/files/ip-consortium/IP%20Website/SIEF%20Communication/2010-05-24_IP24_Bone_ash_SIEF_email_sent.pdf
To-o, K; Kamasaka, H; Nishimura, T; Kuriki, T; Saeki, S; Nakabou, Y. (2003). Absorbability of calcium from calcium-bound phosphoryl oligosaccharides in comparison with that from various calcium compounds in the rat ligated jejunum loop. Biosci Biotechnol Biochem 67: 1713–1718. 10.1271/bbb.67.1713 12951504
Trautvetter, U; Ditscheid, B; Jahreis, G; Glei, M. (2018). Habitual intakes, food sources and excretions of phosphorus and calcium in three german study collectives. Nutrients 10: 171. 10.3390/nu10020171
Trautvetter, U; Neef, N; Leiterer, M; Kiehntopf, M; Kratzsch, J; Jahreis, G. (2014). Effect of calcium phosphate and vitamin D3 supplementation on bone remodelling and metabolism of calcium, phosphorus, magnesium and iron. Nutr J 13: 6. 10.1186/1475-2891-13-6 24438153
U.S. APHC (U.S. Army Public Health Command). (2013). Environmental health risk assessment and chemical exposure guidelines for deployed military personnel. (Technical guide 230, 2013 revision). Aberdeen Proving Ground, MD. https://phc.amedd.army.mil/PHC%20Resource%20Library/TG230-DeploymentEHRA-and-MEGs-2013-Revision.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1988). Recommendations for and documentation of biological values for use in risk assessment [EPA Report]. (EPA/600/6-87/008). Cincinnati, OH. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=34855
U.S. EPA (U.S. Environmental Protection Agency). (2002). A review of the reference dose and reference concentration processes. (EPA/630/P-02/002F). Washington, DC. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2005). Guidelines for carcinogen risk assessment [EPA Report]. (EPA/630/P-03/001F). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3-25-05.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2011). Health effects assessment summary tables (HEAST) for superfund. Available online at https://epa-heast.ornl.gov/heast.php
U.S. EPA (U.S. Environmental Protection Agency). (2018). 2018 Edition of the drinking water standards and health advisories [EPA Report]. (EPA/822/F-18/001). Washington, DC: U.S. Environmental Protection Agency, Office of Water. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2019). The Toxic Substances Control Act’s public inventory (TSCA inventory). Retrieved from https://www.epa.gov/tscainventory/how-access-tsca-inventory#download (https://www.epa.gov/tsca-inventory/how-access-tsca-inventory#download)
U.S. EPA (U.S. Environmental Protection Agency). (2020a). CompTox chemicals dashboard. Washington, DC. Retrieved from https://comptox.epa.gov/dashboard
U.S. EPA (U.S. Environmental Protection Agency). (2020b). Integrated risk information system. IRIS assessments [Database]. Washington, DC. Retrieved from http://www.epa.gov/iris/
Vrana, LM. (2011). Calcium and calcium alloys. In Kirk-Othmer encyclopedia of chemical technology. Hoboken, NJ: John Wiley & Sons, Inc. 10.1002/0471238961.0301120308090202.a01.pub3
Weiner, ML; Salminen, WF; Larson, PR; Barter, RA; Kranetz, JL; Simon, GS. (2001). Toxicological review of inorganic phosphates [Review]. Food Chem Toxicol 39: 759–786. 10.1016/S0278-6915(01)00028-X 11434984
WHO (World Health Organization). (1982). Phosphoric acid and phosphate salts. In Toxicological evaluation of certain food additives and contaminants. (WHO Food Additive Series 17). Geneva, Switzerland: International Programme on Chemical Safety.
Yang, RS; Liu, TK; Tsai, KS. (1994). The acute metabolic effects of oral tricalcium phosphate and calcium carbonate. Calcif Tissue Int 55: 335–341.7866912