# APPENDIX B DATA TABLES

Table B-1 Histopathological Kidney Effects in Parental Sprague Dawley Rats Administered TCP via Gavage during Premating, Mating, Gestation, and until Sacrifice (Males) or LD 4 (Females)^a^

Histopathological Effect | Dose in mg/kg-d
Histopathological Effect | Main Study | | | | Recovery
Histopathological Effect | 0 | 250 | 500 | 1,000 | 0 | 1,000
Males
Tubular degeneration/regeneration
Minimal | 2/5 (40)^b^ | 1/5 (20) | 1/5 (20) | 2/5 (40) | 1/5 (20) | 4/5 (80)
Slight | 0/5 (0) | 1/5 (20) | 1/5 (20) | 3/5 (60) | 0/5 (0) | 0/5 (0)
Total | 2/5 (40) | 2/5 (40) | 2/5 (40) | 5/5 (100) | 1/5 (20) | 4/5 (80)
Females
Mineralization
Minimal | 4/5 (80) | 5/5 (100) | 2/5 (40) | 2/5 (40) | 2/5 (40) | 2/5 (40)
Slight | 0/5 (0) | 0/5 (0) | 2/5 (40) | 2/5 (40) | 0/5 (0) | 1/5 (20)
Total | 4/5 (80) | 5/5 (100) | 4/5 (80) | 4/5 (80) | 2/5 (40) | 3/5 (60)

a NIER (2007) as cited in OECD (2012); no significant changes from control based on Fisher’s exact test (one-sided p < 0.05) conducted for this review.

b Values denote number of animals showing changes ÷ total number of animals examined (percent incidence).

LD = lactation day; TCP = tricalcium phosphate.

Table B-2 Developmental Effects in Dutch Belted Rabbits Administered MCP Monohydrate via Gavage on GDs 6–18^a^

Parameters | Dose in mg/kg-d
Parameters | MCP monohydrate | | | | | 6-AN
Parameters | 0 | 2.17 | 10.10 | 46.7 | 217 | 2.5
Number pregnant^b^ | 12/21 (57) | 12/21 (57) | 17/27 (63) | 10/15 (67) | 10/27 (37) | 9/18 (50)
Mortality prior to GD 29^b^ | 2/12 (17) | 1/12 (8) | 4/17 (24) | 0/10 (0) | 0/10 (0) | 0/9 (0)
Total litter loss^b^ | 0/10 (0) | 1/11 (9) | 0/13 (0) | 1/10 (10) | 2/10 (20) | 1/9 (11)
Number of corpora lutea/doe^c,^ ^d^ | 11.4 ± 5.45 (14) | 9.43 ± 3.81 (14) [−17]^d^ | 9.55 ± 3.26 (20) [−16] | 8.46 ± 2.02 (13) [−26] | 6.37 ± 5.40^*^ (19) [−44] | 9.75 ± 5.61 (12) [−14]
Number of implant sites/doe^c,^ ^d^ | 5.80 ± 1.40 (10) | 5.64 ± 2.01 (11) [−3] | 6.08 ± 2.02 (13) [+5] | 5.00 ± 1.79 (10) [−14] | 4.90 ± 1.97 (10) [−16] | 6.33 ± 2.31 (9) [+9]
Number of live fetuses^c,^ ^d^ | 5.10 ± 2.10 (10) | 4.45 ± 2.54 (11) [−13] | 5.85 ± 2.21 (13) [+15] | 4.30 ± 2.15 (10) [−16] | 4.50 ± 2.62 (10) [−12] | 5.44 ± 2.45 (9) [+7]

a FDRL (1974).

b Values denote number of animals showing changes ÷ total number of animals examined (percent incidence).

c Data are means ± SD (n); SDs were calculated for this review based on raw data provided in the study.

d Percentage value in brackets is percent change relative to control = [(treatment mean − control mean) ÷ control mean] × 100.

* Significantly different from control by t-test (two-tailed; p < 0.05) conducted for this review.

6-AN = 6-aminonicotinamide; GD = gestation day; MCP = monocalcium phosphate; SD = standard deviation.

Table B-3 Developmental Effects in Wistar Rats Administered TCP via Gavage on GDs 0–20^a^

Parameters | Dose in mg/kg-d
Parameters | 0 (untreated control) | 0 (vehicle control) | 175
Weight of placenta (g) | 0.45 ± 0.0007^b^ | 0.44 ± 0.03 | 0.40 ± 0.0006^*^ (−11)^c^
Transumbilical diameter (mm) | 21.27 ± 0.38 | 22.41 ± 0.44 | 24.24 ± 0.45^*,,^ ^†^ (+8)
Skull; diameter of y-axis (mm) | 11.01 ± 0.24 | 10.55 ± 0.29 | 9.65 ± 0.46^*^ (−9)
Left ulna (mm) | 2.30 ± 0.08 | 2.33 ± 0.05 | 1.65 ± 0.20^*,,^ ^†^ (−29)
Right ulna (mm) | 2.38 ± 0.11 | 2.34 ± 0.06 | 1.77 ± 0.20 (−24)
Left femur (mm) | 1.66 ± 0.11 | 1.52 ± 0.05 | 1.08 ± 0.13^*,,^ ^†^ (−29)
Right femur (mm) | 1.71 ± 0.14 | 1.52 ± 0.13 | 1.20 ± 0.11 (−21)

a Güngörmüş et al. (2010).

b Data are means ± SE.

c Value in parentheses is percent change relative to vehicle-only control = [(treatment mean − vehicle control mean) ÷ vehicle control mean] × 100.

* Significantly different from untreated control (p < 0.05), as reported by the study authors.

† Significantly different from vehicle control (p < 0.05), as reported by the study authors.

GD = gestation day; SE = standard error; TCP = tricalcium phosphate.