# APPENDIX A SCREENING PROVISIONAL VALUES

Due to the lack of evidence described in the main Provisional Peer-Reviewed Toxicity Value (PPRTV) document, it is inappropriate to derive provisional toxicity values for calcium phosphate salts. However, some information is available for this chemical, which although insufficient to support deriving a provisional toxicity value under current guidelines, may be of use to risk assessors. In such cases, the Center for Public Health and Environmental Assessment (CPHEA) summarizes available information in an appendix and develops a “screening value.” Appendices receive the same level of internal and external scientific peer review as the provisional reference values to ensure their appropriateness within the limitations detailed in the document. Users of screening toxicity values in an appendix to a PPRTV assessment should understand that there could be more uncertainty associated with the derivation of an appendix screening toxicity value than for a value presented in the body of the assessment. Questions or concerns about the appropriate use of screening values should be directed to the CPHEA.

## DERIVATION OF SCREENING PROVISIONAL REFERENCE DOSES

As discussed in the main body of the report, the only available oral studies with adequate information to derive effect levels, NIER (2009, 2010) as cited in OECD (2011a), NIER (2007) as cited in OECD (2012), and FDRL (1974) were unpublished and/or available only as reported in secondary sources. However, these studies seem to have been well conducted and to provide adequate information for deriving a screening-level provisional toxicity value for calcium phosphate salts.

A no-observed-adverse-effect level (NOAEL) of 1,000 mg/kg-day is identified for dicalcium phosphate (DCP) in a 28-day repeated-dose toxicity study [NIER (2010) as cited in OECD (2011a)] and a reproductive/developmental (R/D) screening test [NIER (2009) as cited in OECD (2011a)], and for tricalcium phosphate (TCP) in a repeated-dose, with R/D toxicity, screening test [NIER (2007) as cited in OECD (2012)] based on the absence of any significant, treatment-related systemic, reproductive, or developmental effects at the highest tested dose. The FDRL (1974) study examined developmental toxicity in rats, mice, and rabbits, and did not observe biologically relevant effects at doses up to 465 mg MCP/kg-day. The lack of developmental effects observed for calcium phosphates is consistent with other inorganic phosphates. For example, developmental effects were not observed in rats treated with ammonium phosphates up to 1,500 mg/kg-day [Huntingdon (2002) as cited in OECD (2007) and ECHA (2002)]. Additionally, developmental effects were not observed in rats, rabbits, mice, or hamsters across multiple studies treated with sodium or potassium phosphates at doses up to 200 mg P/kg-day [e.g., Hodge (1964)], which is higher than the dose of 120 mg P/kg-day (monosodium phosphate) that caused increased incidence of nephrocalcinosis in rabbits (Ritskes-Hoitinga et al., 2004), indicating that systemic toxicity is more sensitive than developmental toxicity. Therefore, the NOAEL of 1,000 mg/kg-day identified for TCP and DCP is considered protective against potential reproductive and developmental toxicity because effects would most likely not have been observed in the FDRL (1974) study if the study authors had tested doses as high as 1,000 mg/kg-day. In the absence of any observed effects for calcium phosphates, these data were not amenable to benchmark dose modeling. Thus, after adjusting for human equivalent dose, the NOAEL (HED)^2^ of 240 mg/kg-day based on the animal dose of 1,000 mg/kg-day, is selected as the point of departure (POD).

### Derivation of Screening Subchronic Provisional Reference Dose

A screening subchronic p-RfD of 8 × 10^0^ mg calcium phosphate salt/kg-day is derived for calcium phosphate salts by applying a composite uncertainty factor (UF_C_) of 30 (reflecting an interspecies uncertainty factor [UF_A_] of 3, an intraspecies uncertainty factor [UF_H_] of 3, and a database uncertainty factor [UF_D_] of 3) to the selected POD of 240-mg DCP or TCP/kg-day (NOAEL [HED]), as follows:

Screening Subchronic p-RfD = NOAEL ( HED ) ÷ UF_C_ = 240 mg DCP or TCP / kg-day ÷ 30 = 8 × 10^0^ mg calcium phosphate salt / kg-day

Table A-1 summarizes the uncertainty factors for the screening subchronic p-RfD for calcium phosphate salts. Although the screening subchronic p-RfD is based on data for DCP and TCP, the value is expected to be protective for all calcium phosphates following application of a molecular weight adjustment and appropriate stoichiometric calculations. Studies of monocalcium phosphate (MCP) evaluating sensitive developmental endpoints identified only NOAELs at the highest doses tested. Although no repeated-dose data are available for calcium pyrophosphate (CPP), data from acute toxicity tests suggest that CPP is similar to or less toxic than other calcium phosphate compounds (likely owing to its lower solubility and resultant lower bioavailability relative to other calcium phosphate salts; see Table 1B and the “Acute Toxicity” sections). However, this screening subchronic RfD should not be applied to the risk assessment of magnesium phosphate salts, which is also a divalent inorganic phosphate, because there are no data with respect to the toxicity of magnesium phosphate salts relative to calcium phosphate salts.

Table A-1 Uncertainty Factors for the Screening Subchronic p-RfD for Calcium Phosphate Salts

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^) is applied to account for uncertainty in characterizing the toxicokinetic or toxicodynamic differences between rats and humans following calcium phosphates exposure. The toxicokinetic uncertainty has been accounted for by calculating an HED through application of a DAF as outlined in the U.S. EPA’s Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 1988).
UF_D_ | 3 | A UF_D_ of 3 is applied to account for deficiencies and uncertainties in the database because no subchronic or chronic-duration oral toxicity studies were identified. However, the database includes multiple R/D studies in various animal species (e.g., rats, mice, and rabbits) treated with various forms of calcium phosphates (e.g., DCP, MCP, and TCP) and repeated-dose toxicity studies up to 28 days.
UF_H_ | 3 | A UF_H_ of 3 is applied to account for human-to-human variability in susceptibility. Based on the comprehensive toxicity database for sodium and potassium phosphates, which included reproductive and developmental toxicity studies, the most sensitive toxicity effect after repeated oral exposure to phosphate is renal toxicity in animals, and the renal toxicity is also the most sensitive effect observed in susceptible humans after repeated exposure. An available animal study on DCP [NIER (2010) as cited in OECD (2011a)] has examined the most sensitive organ (i.e., kidneys). Therefore, the use of a NOAEL based on an animal study on DCP [NIER (2010) as cited in OECD (2011a)] which examined kidney effects as the POD will also protect against most sensitive kidney toxicity in susceptible human populations.
UF_L_ | 1 | A UF_L_ of 1 is applied for LOAEL-to-NOAEL extrapolation because the POD is a NOAEL.
UF_S_ | 1 | A UF_S_ of 1 is applied because the subchronic POD is from 28-d repeated-dose and R/D screening studies for DCP and TCP.
UF_C_ | 30 | Composite UF = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_

DAF = dosimetric adjustment factor; DCP = dicalcium phosphate; HED = human equivalent dose;

LOAEL = lowest-observed-adverse-effect level; MCP = monocalcium phosphate;

NOAEL = no-observed-adverse-effect level; POD = point of departure; p-RfD = provisional reference dose; R/D = reproductive/developmental; TCP = tricalcium phosphate; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

### Consideration of the Recommended Daily Intake

Phosphorus is an essential nutrient that exhibits a U-shaped dose-response curve: doses that are below physiological requirements may lead to deleterious effects, as can doses that exceed physiological requirements. The recommended daily intake (RDI) value for phosphorus is 700 mg phosphorus/day or 10 mg phosphorus/kg-day for a 70-kg adult (EFSA, 2015; IOM, 1997). However, the RDI includes phosphorus from less bioavailable and organic plant and animal sources in addition to inorganic phosphate sources. Furthermore, dietary intake of phosphorus in the U.S. population generally exceeds intake rates that are considered adequate. Using NHANES data between 2001 and 2014, McClure et al. (2017) estimated mean dietary phosphorus intake over the entire period to be 1,373 mg phosphorus/day (range of means by year was 1,324−1,414 mg phosphorus/day), or ~20 mg phosphorus/kg-day for a 70-kg adult. While little information regarding the proportion of total dietary phosphorus load from inorganic phosphate additives (the source most relevant to this assessment) was located, one source estimated the contribution to be ~500 mg phosphorus/day [Calvo and Uribarri (2013) as cited in Trautvetter et al. (2018)]. Given that the RDI of phosphorus includes both organic and inorganic sources, and environmental exposure to inorganic phosphate will increase phosphorus intake over a dietary intake that exceeds adequate intake rates, the RDI is not considered to be a lower bound on the p-RfD for inorganic phosphates.

### Derivation of Screening Chronic Provisional Reference Dose

There are no adequate subchronic or chronic-duration oral studies available for calcium phosphate salts; therefore, data are not adequate for derivation of a screening chronic p-RfD. It is not appropriate to use the NOAEL from the short-term and R/D studies that serve as the basis for the screening subchronic p-RfD to support derivation of a screening chronic p-RfD because it is based on a lack of significant biological effects. It is unknown whether exposure to that NOAEL value would result in adverse effects if exposure continued over a chronic duration.

2 NOAEL (HED) = NOAEL (1,000 mg DCP or TCP) × DAF (0.24). The dosimetric adjustment factor (DAF) is calculated as follows: DAF = (BW_a_^1/4^ ÷ BW_h_^1/4^). Reference body weights for Sprague Dawley rats (average of males and females; 0.236 kg) and humans (70 kg) recommended by U.S. EPA (1988) were used to calculate the DAF. Reference body-weight data were used because study-specific data were not available (study summaries were obtained from secondary sources).