# AUTHORS, CONTRIBUTORS, AND REVIEWERS

## CHEMICAL MANAGER

- Jeffry L. Dean II, PhD
  Center for Public Health and Environmental Assessment, Cincinnati, OH

## CONTRIBUTOR

- Laura M. Carlson, PhD
  Center for Public Health and Environmental Assessment, Research Triangle Park, NC
- Roman Mezencev, PhD
  Center for Public Health and Environmental Assessment, Washington, DC

## SCIENTIFIC TECHNICAL LEAD

- Jeffry L. Dean II, PhD
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- J. Phillip Kaiser, PhD, DABT
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- Q. Jay Zhao, PhD, MPH, DABT
  Center for Public Health and Environmental Assessment, Cincinnati, OH

## DRAFT DOCUMENT PREPARED BY

- SRC, Inc.
  7502 Round Pond Road
  North Syracuse, NY 13212

## PRIMARY INTERNAL REVIEWERS

- Andrew Kraft, PhD
  Center for Public Health and Environmental Assessment, Washington, DC
- Paul G. Reinhart, PhD, DABT
  Center for Public Health and Environmental Assessment, Research Triangle Park, NC

## PRIMARY EXTERNAL REVIEWERS

- Eastern Research Group, Inc.
  110 Hartwell Avenue
  Lexington, MA 02421-3136

## PPRTV PROGRAM MANAGEMENT

- Teresa L. Shannon
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- J. Phillip Kaiser, PhD, DABT
  Center for Public Health and Environmental Assessment, Cincinnati, OH

Questions regarding the content of this PPRTV assessment should be directed to the U.S. EPA Office of Research and Development (ORD) Center for Public Health and Environmental Assessment (CPHEA) website at https://ecomments.epa.gov/pprtv.