# 3 DERIVATION OF PROVISIONAL VALUES

## 3.1 DERIVATION OF PROVISIONAL REFERENCE DOSES

No studies have been identified regarding toxicity of 1-bromo-2-chloroethane to humans by oral exposure. Animal studies of oral exposure to 1-bromo-2-chloroethane are limited to acute studies of inadequate design, duration, and scope to support derivation of a subchronic or chronic provisional reference dose (p-RfD). As a result of the limitations of the available oral toxicity data for 1-bromo-2-chloroethane, subchronic and chronic p-RfDs are not derived directly. Instead, screening subchronic and chronic p-RfDs are derived in Appendix A using an alternative analogue approach. Based on the overall analogue approach presented in Appendix A, 1,2-dibromo-3-chloropropane is selected as the most appropriate analogue for 1-bromo-2-chloroethane for deriving a screening subchronic and chronic p-RfD (see Table 5).

## 3.2 DERIVATION OF PROVISIONAL REFERENCE CONCENTRATIONS

No studies have been identified on the toxicity of 1-bromo-2-chloroethane to humans by inhalation exposure. Animal studies of inhalation exposure to 1-bromo-2-chloroethane are limited to a single acute lethality study of inadequate design, duration, and scope to support derivation of a subchronic or chronic provisional reference concentrations (p-RfCs). Due to lack of adequate inhalation toxicity data for 1-bromo-2-chloroethane, subchronic and chronic p-RfCs are not derived directly. Instead, screening subchronic and chronic p-RfCs are derived in Appendix A using an alternative analogue approach. Based on the overall analogue approach presented in Appendix A, 1,2-dibromo-3-chloropropane is selected as the most appropriate analogue for 1-bromo-2-chloroethane for deriving a screening subchronic and chronic p-RfC (see Table 5).

## 3.3 SUMMARY OF NONCANCER PROVISIONAL REFERENCE VALUES

The noncancer screening provisional reference values for 1-bromo-2-chloroethane are summarized in Table 5.

Table 5 Summary of Noncancer Reference Values for 1-Bromo-2-Chloroethane (CASRN 107-04-0)

Toxicity Type (units) | Species/Sex | Critical Effect | p-Reference Value | POD Method | POD | UF_C_ | Principal Study
Screening subchronic p-RfD (mg/kg-d) | Rabbit/M | Reduced germ cell number | 1 × 10^−3^ | NOAEL (HED) | 0.3; (based on analogue POD) | 300 | Foote et al. (1986a, b) as cited in U.S. EPA (2006)
Screening chronic p-RfD (mg/kg-d) | Rabbit/M | Reduced germ cell number | 1 × 10^−4^ | NOAEL (HED) | 0.3; (based on analogue POD) | 3,000 | Foote et al. (1986a, b) as cited in U.S. EPA (2006)
Screening subchronic p-RfC (mg/m^3^) | Rabbit/M | Testicular toxicity | 6 × 10^−4^ | NOAEL (HEC) | 0.17; (based on analogue POD) | 300 | Rao et al. (1982) as cited in U.S. EPA (2006)
Screening chronic p-RfC (mg/m^3^) | Rabbit/M | Testicular toxicity | 6 × 10^−5^ | NOAEL (HEC) | 0.17; (based on analogue POD) | 3,000 | Rao et al. (1982) as cited in U.S. EPA (2006)

HEC = human equivalent concentration; HED = human equivalent dose; M = male(s); NOAEL = no-observed-adverse-effect level; POD = point of departure; p-RfC = provisional reference concentration; p-RfD = provisional reference dose; UF_C_ = composite uncertainty factor.

## 3.4 CANCER WEIGHT-OF-EVIDENCE DESCRIPTOR

Although the scientific literature provides information on the mutagenicity and genotoxicity of 1-bromo-2-chloroethane, no studies have been conducted to directly assess its carcinogenicity. Under the U.S. EPA Cancer Guidelines (U.S. EPA, 2005), there is “Inadequate Information to Assess the Carcinogenic Potential” of 1-bromo-2-chloroethane (see Table 6).

Within the current U.S. EPA Cancer Guidelines (U.S. EPA, 2005), there is no standard methodology to support the identification of a weight-of-evidence (WOE) descriptor and derivation of provisional cancer risk estimates for data-poor chemicals using an analogue approach. In the absence of an established framework, a screening evaluation of potential carcinogenicity is provided using the methodology described in Appendix B. This evaluation determined that there was a qualitative level of concern for potential carcinogenicity for 1-bromo-2-chloroethane (see Appendix C).

Table 6 Cancer WOE Descriptor for 1-Bromo-2-Chloroethane (CASRN 107-04-0)

Possible WOE Descriptor | Designation | Route of Entry (oral, inhalation, or both) | Comments
“Carcinogenic to Humans” | NS | NA | No human data are available.
“Likely to Be Carcinogenic to Humans” | NS | NA | No adequate chronic-duration animal cancer bioassays are available.
“Suggestive Evidence of Carcinogenic Potential” | NS | NA | No adequate chronic-duration animal cancer bioassays are available.
“Inadequate Information to Assess Carcinogenic Potential” | Selected | Both | No studies are available assessing the carcinogenic potential of 1-bromo-2-chloroethane in humans or animals.
“Not Likely to Be Carcinogenic to Humans” | NS | NA | No evidence of noncarcinogenicity is available. No adequate chronic-duration animal cancer bioassays are available.

NA = not applicable; NS = not selected; WOE = weight of evidence.

## 3.5 DERIVATION OF PROVISIONAL CANCER RISK ESTIMATES

The absence of suitable data precludes development of cancer risk estimates for 1-bromo-2-chloroethane (see Table 7).

Table 7 Summary of Cancer Risk Estimates for 1-Bromo-2-Chloroethane (CASRN 107-04-0)

Toxicity Type (units) | Species/Sex | Tumor Type | Cancer Risk Estimate | Principal Study
Screening p-OSF (mg/kg-d)^−1^ | NDr
Screening p-IUR (μg/m^3^)^−1^ | NDr

NDr = not determined; p-IUR = provisional inhalation unit risk; p-OSF = provisional oral slope factor.