# 2 REVIEW OF POTENTIALLY RELEVANT DATA (NONCANCER AND CANCER)

As shown in Tables 3A and 3B, there are no potentially relevant short-term, subchronic, chronic, developmental, or reproductive toxicity studies of 1-bromo-2-chloroethane in humans or animals exposed by oral or inhalation routes. The phrase “statistical significance” or the term “significant,” used throughout the document, indicates a p-value of < 0.05 unless otherwise noted.

Table 3A Summary of Potentially Relevant Noncancer Data for 1-Bromo-2-Chloroethane (CASRN 107-04-0)

Category | Number of Male/Female, Strain, Species, Study Type, Reported Doses, Study Duration | Dosimetry | Critical Effects | Reference | Notes
Human
1. Oral (mg/kg-d)
ND
2. Inhalation (mg/m^3^)
ND
Animal
1. Oral (mg/kg-d)
ND
2. Inhalation (mg/m^3^)
ND

ND = no data.

Table 3B Summary of Potentially Relevant Cancer Data for 1-Bromo-2-Chloroethane (CASRN 107-04-0)

Category | Number of Male/Female, Strain, Species, Study Type, Reported Doses, Study Duration | Dosimetry | Critical Effects | Reference | Notes
Human
1. Oral (mg/kg-d)
ND
2. Inhalation (mg/m^3^)
ND
Animal
1. Oral (mg/kg-d)
ND
2. Inhalation (mg/m^3^)
ND

ND = no data.

## 2.1 HUMAN STUDIES

### 2.1.1 Oral Exposures

No human studies following oral exposure to 1-bromo-2-chloroethane have been identified.

### 2.1.2 Inhalation Exposures

No human studies following inhalation exposure to 1-bromo-2-chloroethane have been identified.

## 2.2 ANIMAL STUDIES

### 2.2.1 Oral Exposures

No animal studies following oral exposure to 1-bromo-2-chloroethane have been identified.

### 2.2.2 Inhalation Exposures

No animal studies following inhalation exposure to 1-bromo-2-chloroethane have been identified.

## 2.3 OTHER DATA (SHORT-TERM TESTS, OTHER EXAMINATIONS)

Toxicity data for 1-bromo-2-chloroethane are limited to acute lethality values reported in secondary sources, an acute oral hepatotoxicity study, an acute intraperitoneal (i.p.) injection study, and genotoxicity studies.

### 2.3.1 Acute Toxicity in Animals

An oral median lethal dose (LD_50_) value of 64 mg/kg was identified for 1-bromo-2-chloroethane in rats [Frear (1969) as cited in NLM (2016)]; no further data regarding acute oral toxicity were reported. Valade (1957), as cited in U.S. EPA (1985), reported a 30-minute median lethal concentration (LC_50_) value of 15,000−25,000 mg/m^3^ for 1-bromo-2-chloroethane in unspecified laboratory animals. This study also indicated that acute inhalation of “several alkyl halides” caused ataxia in dogs, rats, and guinea pigs; however, it is unclear whether these halides included 1-bromo-2-chloroethane.

Moody et al. (1980) treated male Sprague Dawley rats with 1-bromo-2-chloroethane via gavage and found decreases in cytochrome P450 (CYP450) content of hepatic microsomes to 51% of controls, as well as alterations in relative content of fatty acids within hepatic microsomes 18 hours after exposure to a single dose (0.15 mL/kg). A high correlation between CYP450 loss and decreased arachidonic acid, increased linoleic acid, and increased oleic acid was observed.

Significant mortality was observed in male B6C3F1 mice (5/11 treated animals) at 24 hours following a single i.p. injection of 1.5 mmol/kg (215 mg/kg) of 1-bromo-2-chloroethane. Statistically significant increases in serum sorbitol dehydrogenase (SDH), alanine aminotransferase (ALT), and blood urea nitrogen (BUN) and relative liver and kidney weights were also observed at this dose (Storer and Conolly, 1983). No mortalities or liver or kidney effects were noted at ≤1 mmol/kg (143 mg/kg); no other endpoints were evaluated.

### 2.3.2 Genotoxicity

Overview: Studies evaluating the potential genotoxicity of 1-bromo-2-chloroethane are summarized below (see Table 4 for details). Available data indicate that 1-bromo-2-chloroethane and/or its metabolites display genotoxic, mutagenic, clastogenic, and deoxyribonucleic acid (DNA) damaging activity.

Table 4 Summary of 1-Bromo-2-Chloroethane (CASRN 107-04-0) Genotoxicity

Endpoint | Test System | Doses/Concentrations Tested | Results without Activation^a^ | Results with Activation^a^ | Comments | References (comments)
Genotoxicity studies in prokaryotic organisms
Mutation | Salmonella typhimurium strains TA1535, TA1537, TA1538, TA98, and TA100 | 0, 1.6, 3.0, 4.7, 6.8, 8.1 µmol/plate | +; (TA1535, TA100); −; (TA1537, TA1538, TA98) | +; (TA1535, TA100); −; (TA1537, TA1538, TA98) | A concentration-dependent increase in revertants was observed in TA1535 and TA100 with or without metabolic activation (rat liver S9 fractions). The addition of S9 activation did not significantly increase the mutagenic response. | Barber et al. (1981)
Mutation | S. typhimurium strains TA1530, TA1535, and TA1538 | 0−15 µmol/plate | +; (TA1530, TA1535); -; (TA1538) | NT | A concentration-dependent increase in revertants was observed without metabolic activation. | Brem et al. (1974)
Mutation | S. typhimurium strains TA100 and TA98 | 0, 33, 100, 200, 333, 667, 1,000, 1,500, 2,000 μg/plate | +; (TA100, TA98) | +; (TA100); −; (TA98) | In TA100, the number of revertants was increased >twofold at ≥667 μg/plate without metabolic activation and ≥333 μg/plate with metabolic activation. In TA98, the number of revertants was increased >twofold at ≥333 μg/plate without metabolic activation. | NTP (1990)
Mutation | S. typhimurium strains TA100 and TA102 | NR | + | (see comments) | Preincubation assay. It is unclear from the abstract whether or not metabolic activation was used. | Hughes et al. (1987) (abstract only)
Mutation | S. typhimurium strains; TA1535/pK233-2 (empty plasmid); TA1535/DM11 (bacterial dichloromethane dehalogenase); TA1535/GST 5-5 (rat GST); TA1535/GST T1 (human GST) | 0−10.0 µM (DM11);; 0−150 µM (GST 5-5, GST T1, and control plasmid pK233-2) | −; (pK233-2) | +; (DM11, GST 5-5, GST T1) | Metabolic activation was achieved using S. typhimurium TA1535 cells expressing mammalian theta-class GSH transferases (rat GST 5-5 or human GST T1) or a bacterial dichloromethane dehalogenase (DM11).; A concentration-dependent increase in revertants was observed for each of the enzymes induced; an increase in revertants was not observed in TA1535 with the expression plasmid only. The numbers of revertants/µM per plate for GST 5-5, GST T1, and DM11 were 45, 3.3, and 2,200, respectively. It was <0.1 for the plasmid only. | Wheeler et al. (2001)
Mutation | S. typhimurium strain TA100 | 0−4.0 mM | + | + | Metabolic activation was tested either with rat GSH added or rat GSH + rat liver cytosol (S100). The number of revertants following GSH + S100 activation was increased almost fourfold over GSH only or without a metabolizing system. | van Bladeren et al. (1981)
DNA damage (SOS/umu chromotest) | S. typhimurium strains; TA1535/pSK1002 (empty plasmid); NM5004; (rat GST 5-5 and umuC-lac Z operon) | 0−0.5 mM | −; (pSK1002) | +; (NM5004) | Strain NM5004 was generated by introducing a plasmid S. typhimurium TA1535 cells containing both rat GSH transferase (GST 5-5) cDNA and the umuC-lac Z operon.; Umu gene expression was increased in a dose-dependent manner for NM5004 at noncytotoxic concentrations. Cytotoxicity was observed at ≥0.25 mM in the NM5004 strain. | Shimada et al. (1996)
DNA damage (SOS/umu chromotest) | S. typhimurium strains; TA1535/pSK1002 (empty plasmid); NM5004; (rat GST 5-5 and umuC-lac Z operon) | 0−0.1 mM | −; (pSK1002) | +; (NM5004) | Strain NM5004 was generated as describe above by Shimada et al. (1996).; Umu gene expression was increased in a dose-dependent manner for NM5004 at noncytotoxic concentrations. Cytotoxicity was observed at 0.1 mM in the NM5004 strain. | Oda et al. (1996)
Genotoxicity studies in nonmammalian eukaryotic organisms
Mitotic malsegregation | Aspergillus nidulans diploid strain P1 | 0, 6.0, 12.0, 18.0, 24.0 mM | + | + | The number of malsegregations was significantly elevated at ≥12.0 mM; survival was <50% at ≥18.0 mM. | Crebelli et al. (1995)
Mitotic recombination (wing-spot test) | Drosophila melanogaster (flr^3^ × mwh); 48-h inhalation exposure | 0, 0.31 µg/L | + | + | The tested concentration was based on the calculated LC_50_. The frequency of wing spots at the LC_50_ was significantly elevated by 17-fold compared with controls. | Chroust et al. (2006)
Genotoxicity studies in mammalian cells in vitro
HGPRT mutation (6-thioguanine resistance) | CHO cells | +S9: 0, 0.05, 0.1, 0.2, 0.3, 0.4, 0.5, 0.6, 0.7, 0.8, 1.0 mM;; −S9: 0, 0.5, 1, 2, 3, 4, 6, 8 mM | + | + | A concentration-dependent increase in mutants was observed with and without metabolic activation; the mutagenic activity was fourfold greater with metabolic activation (rat liver S9 mix) than without S9. Enhancement by S9 mix did not occur when the NADPH pool was reduced (via omission of NADP from the S9 fraction). Cell survival (relative to untreated control) was reduced by >50% at 6 mM without S9 and 1 mM with S9. | Tan and Hsie (1981)
CAs | CHL cells | 0.1−0.5 mg/mL (6 h; ±S9); 0.5−3.0 mg/mL (24 h; −S9); 0.5−4.0 mg/mL (48 h); −S9 | +; (24 h; 48 h); −; (6 h) | +; (6 h) | NA | Japan Chemical Industry Ecology-Toxicology Information Center (1996) as cited in NLM (2005)
Genotoxicity studies in mammals in vivo
DNA damage (DNA unwinding assay) | Male B6C3F1 mice (six/group); single i.p. injection; sacrifice 4 h after exposure; hepatic cell nuclei were harvested | 0, 0.5, 0.75, 1.0 mmol/kg | + | + | 1-Bromo-2-chloroethane induced 8.9, 15.8, and 24.7% reduction in double-stranded DNA in liver cells harvested from mice exposed to 0.5, 0.75, and 1.0 mM/kg (72, 107, and 143 mg/kg), respectively, compared with control. | Storer and Conolly (1983)

a + = positive; ± = weakly positive; − = negative.

CA = chromosomal aberration; cDNA = complementary DNA; CHL = Chinese hamster lung; CHO = Chinese hamster ovary (cell line cells); DNA = deoxyribonucleic acid; GSH = glutathione; GST = glutathione-S-transferase; HGPRT = hypoxanthine-guanine phosphoribosyltransferase; i.p. = intraperitoneal; LC_50_ = median lethal concentration; NA = not applicable; NADP = nicotinamide adenine dinucleotide phosphate; NADPH = reduced form of NADP; NR = not reported, NT = not tested.

1-Bromo-2-chloroethane is mutagenic in bacterial and mammalian cells in vitro, both with and without metabolic activation (Wheeler et al., 2001; NTP, 1990; Hughes et al., 1987; Barber et al., 1981; Tan and Hsie, 1981; van Bladeren et al., 1981; Brem et al., 1974). Addition of glutathione-S-transferases (GST) or glutathione (GSH) with or without S100 into Salmonella typhimurium bacterial test systems enhanced mutagenicity, indicating that GSH conjugation results in the formation of mutagenic metabolites (Wheeler et al., 2001; van Bladeren et al., 1981). In the Chinese hamster ovary cell/hypoxanthine-guanine phosphoribosyl transferase (CHO/HGPRT) system, mutagenicity was enhanced in the presence of an S9 metabolic activation fraction; this enhancement did not occur when nicotinamide adenine dinucleotide phosphate (NADP) was omitted from the S9 fraction, suggesting that CYP450 enzymes could be involved in the increased metabolic activation (Tan and Hsie, 1981).

Chromosomal damage and mitotic malsegregation/recombination have been induced by 1-bromo-2-chloroethane in mammalian cells and nonmammalian eukaryotic organisms. 1-bromo-2-chloroethane induced chromosomal aberrations (CAs) in Chinese hamster lung (CHL) cells, both in the presence and absence of a metabolic activation system, in a study by the Japan Chemical Industry Ecology-Toxicology Information Center, available only as a brief summary in the Chemical Carcinogenesis Research Information System (CCRIS) (NLM, 2005). 1-Bromo-2-chloroethane also induced mitotic malsegregation in Aspergillus nidulans (Crebelli et al., 1995) and mitotic recombination in Drosophila melanogaster (Chroust et al., 2006).

DNA damage has been reported in bacterial cells exposed to 1-bromo-2-chloroethane in the presence of GSTs (Oda et al., 1996; Shimada et al., 1996). DNA damage was assessed in the SOS/umu test system, which measures the induction of DNA damage responsive umuC gene expression by cellular β-galactosidase activity produced by an umuC-lac Z fusion gene. Shimada et al. (1996) constructed a strain of S. typhimurium for use in the SOS/umu test system that possessed enhanced GST activity by introducing a rat GST 5-5 cDNA plasmid into S. typhimurium TA1535 (resulting in strain NM5004). Expression of the umuC gene was not increased in the tester TA1535 strain containing only the empty plasmid (pSK1002), but it was increased in a dose-related manner in the NM5004 strain expressing rat GST. These data suggest that GSH conjugates of 1-bromo-2-chloroethane were DNA-reactive intermediates.

DNA damage was also observed in liver cells from male B6C3F1 mice following a single i.p. dose of 1-bromo-2-chloroethane at greater than or equal to 0.5 mmol/kg (72 mg/kg) (Storer and Conolly, 1983). Liver cell nuclei harvested from exposed mice showed a dose-related decrease in the percentage of double-stranded DNA observed (indicating a dose-related increase in DNA damage), as assessed by an alkaline DNA unwinding/hydroxylapatite batch chromatography method.

In summary, 1-bromo-2-chloroethane displayed mutagenic activity among in vitro models employing bacterial and mammalian cells, and this mutagenic activity was increased concomitantly with an increase in GSH conjugation (Wheeler et al., 2001; NTP, 1990; Hughes et al., 1987; Tan and Hsie, 1981; van Bladeren et al., 1981; Brem et al., 1974). Increased CYP450 activity (as suggested by manipulating NADP levels within the S9 fraction) promoted elevated mutagenicity in a CHO/HGPRT model system, indicating a potential role for CYP450 in the mutagenicity resulting from 1-bromo-2-chloroethane metabolism (Tan and Hsie, 1981). Chromosomal aberrations and mitotic malsegregation were increased in both nonmammalian eukaryotic organisms and mammalian cell model systems (Chroust et al., 2006; NLM, 2005; Crebelli et al., 1995). Lastly, the induction of DNA damage in bacterial systems, as well as in in vivo liver cells of male B6C3F1 mice, occurred in a dose-dependent manner after 1-bromo-2-chloroethane exposure (Oda et al., 1996; Shimada et al., 1996; Storer and Conolly, 1983).

### 2.3.3 Absorption, Distribution, Metabolism, and Excretion Studies

Available in vivo and in vitro data indicate that 1-bromo-2-chloroethane is metabolized by a GSH conjugation pathway (Jean and Reed, 1992; Marchand and Reed, 1989). GSH conjugation was demonstrated in vivo by the detection of S-(2-chloroethyl)glutathione (CEG) and its hydrolysis product, S-(2-hydroxyethyl)glutathione (HEG), in the bile of bile-duct-cannulated rats following intravenous (i.v.) injection with 75 mg/kg 1-bromo-2-chloroethane (Marchand and Reed, 1989). The total amount of CEG detected in bile was 2% of the administered dose. Marchand and Reed (1989) suggested that the low levels of CEG detected in bile may result from rapid conversion of CEG to other metabolites (e.g., HEG) or intrahepatic transport of CEG into plasma rather than bile. Data from the structurally similar dihaloalkanes 1,2-dichloroethane and 1,2-dibromoethane indicate that once formed, CEG will cyclize to form an electrophilic episulfonium ion in vivo, which subsequently binds to DNA [reviewed by Guengerich (1994) and Dekant and Vamvakas (1993)].

In isolated rat hepatocytes, 1-bromo-2-chloroethane was metabolized to HEG, S-(carboxymethyl)glutathione (CMG), and S,S′-(1,2-ethanediyl)bis(glutathione) (EDG) conjugates. HEG was produced in the largest amounts, followed by EDG and CMG (Jean and Reed, 1992). HEG and EDG are products of direct GSH conjugation (EDG results from conjugation at both carbon atoms), whereas CMG is formed after an initial oxidation to 2-haloacetaldehyde metabolites (Jean and Reed, 1992). Formation of GSH conjugates was concomitant with intracellular GSH depletion, measured as an 84% decrease in intracellular GSH levels in response to 1-bromo-2-chloroethane treatment. The addition of extracellular GSH into the incubation medium increased the formation of EDG conjugates by 179% (Jean and Reed, 1992). Combined, these data suggest that GSH conjugation is a primary and likely rate-limiting step in the metabolic activation of 1-bromo-2-chloroethane.

No data are available on the absorption, distribution, or excretion of 1-bromo-2-chloroethane.