# 1 INTRODUCTION

1-Bromo-2-chloroethane (CASRN 107-04-0) belongs to the class of compounds known as halogenated alkanes. 1-Bromo-2-chloroethane currently has no commercial uses, but small amounts may be imported and used for research and development (U.S. EPA, 2015b). It is listed under the U.S. Environmental Protection Agency (U.S. EPA) Toxic Substances Control Act (TSCA) Significant New Use Rule (SNUR), which requires notification of the U.S. EPA prior to manufacturing, importing, or processing of a chemical substance for a significant new use (e.g., commercial purpose) (U.S. EPA, 2015c). Former uses of 1-bromo-2-chloroethane include as a solvent for cellulose esters and ethers, in organic synthesis, and as a fumigant for fruits and vegetables (Lewis and Hawley, 2007). 1-Bromo-2-chloroethane is listed on TSCA’s public inventory (U.S. EPA, 2015a), but it is not registered with Europe’s Registration, Evaluation, Authorisation and Restriction of Chemicals (REACH) program (ECHA, 2015).

1-Bromo-2-chloroethane can be produced by the reaction of bromine and chlorine on ethylene gas (Lewis and Hawley, 2007). However, it is no longer produced in the United States because of potential carcinogenic activity based on its in vitro mutagenicity and the carcinogenicity of the structurally similar chemicals 1,2-dibromoethane and 1,2-dichloroethane (U.S. EPA, 2015b).

The empirical formula for 1-bromo-2-chloroethane is C_2_H_4_BrCl, and its structure is shown in Figure 1. Table 1 summarizes its physicochemical properties. 1-Bromo-2-chloroethane is a clear, colorless liquid with a sweet chloroform-like odor at room temperature (NOAA, 2015). Its high vapor pressure indicates that it will exist solely as a vapor in the atmosphere. Given its vapor pressure and moderate estimated Henry’s law constant, it is likely to volatilize from either dry or moist soil surfaces and from water surfaces. The high water solubility and low soil adsorption coefficient indicate that it will have the potential to leach to groundwater or undergo runoff after a rain event. However, volatilization to the atmosphere is expected to be the main transport pathway. Estimated hydrolysis half-lives of 3 and 32 years at pH 8 and 7, respectively, indicate that hydrolysis is not likely to be an important fate process.

Figure 1 1-Bromo-2-Chloroethane (CASRN 107-04-0) Structure

This is the beginning of the long description for Figure 1. Figure 1 is titled 1 Bromo 2 Chloroethane, C A S Registry Number 1 0 7 dash 0 4 dash 0, Structure. The chemical has the empirical formula of C 2 H 4 B r C l. This is the end of the long description for Figure 1.

Table 1 Physicochemical Properties of 1-Bromo-2-Chloroethane (CASRN 107-04-0)

Property (unit) | Value
Physical state | Liquid
Boiling point (°C) | 107^a^
Melting point (°C) | −16.3^a^
Density (g/cm^3^) | 1.63 (predicted average)^a^
Vapor pressure (mm Hg at 20°C) | 33.1^a^
pH (unitless) | NA
pKa (unitless) | NA
Solubility in water (mol/L) | 4.79 × 10^−2^ ^a^
Octanol-water partition coefficient (log K_ow_) | 1.86 (predicted average)^a^
Henry’s law constant (atm-m^3^/mol at 25°C) | 9.09 × 10^−4^ ^a^
Soil adsorption coefficient K_oc_ (L/kg) | 55.1 (predicted average)^a^
Atmospheric OH rate constant (cm^3^/molecule-sec at 25°C) | 3.22 × 10^−13^ (predicted average)^a^
Atmospheric half-life (days) | 42 (estimated)^c^
Relative vapor density (air = 1) | 4.94^b^
Molecular weight (g/mol) | 143^a^
Flash point (closed cup, °C) | NA

a U.S. EPA CompTox Chemicals Dashboard (as of June 2021; https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID4024775#properties).

b NOAA (2015).

c U.S. EPA (2012).

NA = not applicable.

No toxicity values are available for 1-bromo-2-chloroethane from U.S. EPA or other agencies/organizations (see Table 2).

Table 2 Summary of Available Toxicity Values for 1-Bromo-2-Chloroethane (CASRN 107-04-0)

Source^a^ | Value | Notes | Reference^b^
Noncancer
IRIS | NV | NA | U.S. EPA (2020c)
HEAST | NV | NA | U.S. EPA (2011b)
DWSHA | NV | NA | U.S. EPA (2018)
ATSDR | NV | NA | ATSDR (2018)
IPCS | NV | NA | IPCS (2020)
CalEPA | NV | NA | CalEPA (2019)
OSHA | NV | NA | OSHA (2020a); OSHA (2020b)
NIOSH | NV | NA | NIOSH (2018)
ACGIH | NV | NA | ACGIH (2020)
HEEP | NV | NA | U.S. EPA (1985)
Cancer
IRIS | NV | NA | U.S. EPA (2020c)
HEAST | NV | NA | U.S. EPA (2011b)
DWSHA | NV | NA | U.S. EPA (2018)
NTP | NV | NA | NTP (2016a)
IARC | NV | NA | IARC (2018)
CalEPA | NV | NA | CalEPA (2019)
ACGIH | NV | NA | ACGIH (2020)

a Sources: ACGIH = American Conference of Governmental Industrial Hygienists; ATSDR = Agency for Toxic Substances and Disease Registry; CalEPA = California Environmental Protection Agency; DWSHA = Drinking Water Standards and Health Advisories; HEAST = Health Effects Assessment Summary Tables; HEEP = Health and Environmental Effects Profile; IARC = International Agency for Research on Cancer; IPCS = International Programme on Chemical Safety; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration.

b Reference date is the publication date for the database and not the date the source was accessed.

NA = not applicable; NV = not available.

Non-date-limited literature searches were conducted in November 2017 and updated in May 2021, for studies relevant to the derivation of provisional toxicity values for 1-bromo-2-chloroethane (CASRN 107-04-0). Searches were conducted using U.S. EPA’s Health and Environmental Research Online (HERO) database of scientific literature. HERO searches the following databases: PubMed, TOXLINE^1^ (including TSCATS1), and Web of Science. The following resources were searched outside of HERO for health-related values: American Conference of Governmental Industrial Hygienists (ACGIH), Agency for Toxic Substances and Disease Registry (ATSDR), California Environmental Protection Agency (CalEPA), Defense Technical Information Center (DTIC), European Centre for Ecotoxicology and Toxicology of Chemicals (ECETOC), European Chemicals Agency (ECHA), U.S. EPA Chemical Data Access Tool (CDAT), U.S. EPA ChemView, U.S. EPA Integrated Risk Information System (IRIS), U.S. EPA Health Effects Assessment Summary Tables (HEAST), U.S. EPA Office of Water (OW), International Agency for Research on Cancer (IARC), U.S. EPA TSCATS2/TSCATS8e, U.S. EPA High Production Volume (HPV), Chemicals via IPCS INCHEM, Japan Existing Chemical Data Base (JECDB), Organisation for Economic Cooperation and Development (OECD) Screening Information Data Sets (SIDS), OECD International Uniform Chemical Information Database (IUCLID), OECD HPV, National Institute for Occupational Safety and Health (NIOSH), National Toxicology Program (NTP), Occupational Safety and Health Administration (OSHA), and World Health Organization (WHO).

1 Note that this version of TOXLINE is no longer updated (https://www.nlm.nih.gov/databases/download/toxlinesubset.html); therefore, it was not included in the literature search update from May 2021.