# APPENDIX D REFERENCES

ACGIH (American Conference of Governmental Industrial Hygienists). (2020). 2020 TLVs and BEIs: Based on the documentation of the threshold limit values for chemical substances and physical agents & biological exposure indices. Cincinnati, OH.
Akiba, N; Shiizaki, K; Matsushima, Y; Endo, O; Inaba, K; Totsuka, Y. (2017). Influence of GSH S-transferase on the mutagenicity induced by dichloromethane and 1,2-dichloropropane. Mutagenesis 32: 455–462. 10.1093/mutage/gex014 28521016
Amann, RP; Berndtson, WE. (1986). Assessment of procedures for screening agents for effects on male reproduction: Effects of dibromochloropropane (DBCP) on the rat. Fundam Appl Toxicol 7: 244–255. 10.1016/0272-0590(86)90154-5 3758542
ATSDR (Agency for Toxic Substances and Disease Registry). (2001). Toxicological profile for 1,2-dichloroethane [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. https://www.atsdr.cdc.gov/ToxProfiles/tp.asp?id=592&tid=110
ATSDR (Agency for Toxic Substances and Disease Registry). (2018). Minimal risk levels (MRLs). June 2018. Atlanta, GA: Agency for Toxic Substances and Disease Registry (ATSDR).
Barber, ED; Donish, WH; Mueller, KR. (1981). A procedure for the quantitative measurement of the mutagenicity of volatile liquids in the Ames Salmonella/microsome assay. Mutat Res Genet Toxicol 90: 31–48. 10.1016/0165-1218(81)90048-3
Brem, H; Stein, AB; Rosenkranz, HS. (1974). The mutagenicity and DNA-modifying effect of haloalkanes. Cancer Res 34: 2576–2579.4607208
CalEPA (California Environmental Protection Agency). (1999a). Public health goal for 1,2-dichloroethane in drinking water. Sacramento, CA: Office of Environmental Health Hazard Assessment. https://oehha.ca.gov/media/downloads/pesticides/report/12dcaf.pdf
CalEPA (California Environmental Protection Agency). (1999b). Public health goal for 1,2-dichloropropane in drinking water. Sacramento, CA: Office of Environmental Health Hazard Assessment, Pesticide and Environmental Toxicology Section. https://oehha.ca.gov/media/downloads/water/public-health-goal/12dcpf.pdf
CalEPA (California Environmental Protection Agency). (2004). No significant risk level (NSRL) for the proposition 65 carcinogen 1,2-dichloropropane. Sacramento, CA: Office of Environmental Health Hazard Assessment. https://oehha.ca.gov/media/downloads/crnr/oehha2004a.pdf
CalEPA (California Environmental Protection Agency). (2009). Public health goals for chemicals in drinking water: 1,2,3-trichloropropane. Sacramento, CA: Office of Environmental Health Hazard Assessment. https://oehha.ca.gov/media/downloads/water/chemicals/phg/082009tcpphg.pdf
CalEPA (California Environmental Protection Agency). (2011). Air Toxics Hot Spots program technical support document for cancer potencies. Appendix B. Chemical-specific summaries of the information used to derive unit risk and cancer potency values. Updated 2011. Sacramento, CA: Office of Environmental Health Hazard Assessment. https://oehha.ca.gov/air/crnr/technical-support-document-cancer-potency-factors-2009
CalEPA (California Environmental Protection Agency). (2018). Chemicals known to the state to cause cancer or reproductive toxicity May 25, 2018. (Proposition 65 list). Sacramento, CA: Office of Enironmental Health Hazard Assessment. http://oehha.ca.gov/proposition-65/proposition-65-list
CalEPA (California Environmental Protection Agency). (2019). Consolidated table of OEHHA/ARB approved risk assessment health values (September 19, 2019 ed.). Sacramento, CA: California Air Resources Board. https://www.arb.ca.gov/toxics/healthval/contable.pdf
CalEPA (California Environmental Protection Agency). (2020). Hot spots unit risk and cancer potency values. Appendix A. Updated October 2020. Sacramento, CA: Office of Environmental Health Hazard Assessment. https://oehha.ca.gov/media/downloads/crnr/appendixa.pdf
Cheever, KL; Cholakis, JM; El-Hawari, AM; Kovatch, RM; Weisburger, EK. (1990). Ethylene dichloride: The influence of disulfiram or ethanol on oncogenicity, metabolism, and DNA covalent binding in rats. Toxicol Sci 14: 243–261. 10.1016/0272-0590(90)90205-X
ChemIDplus. (2021). ChemIDplus advanced. Available online at https://chem.nlm.nih.gov/chemidplus/
Chroust, K; Pavlová, M; Prokop, Z; Mendel, J; Božková, K; Kubát, Z; Zaji, CV; Damborský, J. (2006). Quantitative structure-activity relationships for toxicity and genotoxicity of halogenated aliphatic compounds: Wing spot test of Drosophila melanogaster. Chemosphere 67: 152–159. 10.1016/j.chemosphere.2006.09.020 17113125
Clark, HA; Snedeker, SM. (2005). Critical evaluation of the cancer risk of dibromochloropropane (DBCP) [Review]. J Environ Sci Health C Environ Carcinog Ecotoxicol Rev 23: 215–260. 10.1080/10590500500234996 16291528
CPDB (Carcinogenic Potency Database). (2011). The carcinogenic potency project: The carcinogenic potency database [Database]: Department of Energy; National Cancer Institute; Environmental Protection Agency; National Institute of Environmental Health Sciences; National Toxicology Program; University of California, Berkeley. Retrieved from https://www.nlm.nih.gov/databases/download/cpdb.html
Crebelli, R; Andreoli, C; Carere, A; Conti, L; Crochi, B; Cotta-Ramusino, M; Benigni, R. (1995). Toxicology of halogenated aliphatic hydrocarbons: Structural and molecular determinants for the disturbance of chromosome segregation and the induction of lipid peroxidation. Chem Biol Interact 98: 113–129. 10.1016/0009-2797(95)03639-3 8548852
Daniel, FB; Robinson, M; Olson, GR; York, RG; Condie, LW. (1994). Ten and ninety-day toxicity studies of 1,2-dichloroethane in Sprague-Dawley rats. Drug Chem Toxicol 17: 463–477. 10.3109/01480549409014312 7821233
Dekant, W; Vamvakas, S. (1993). Glutathione-dependent bioactivation of xenobiotics [Review]. Xenobiotica 23: 873–887. 10.3109/00498259309059415 8284943
Dohn, DR; Graziano, MJ; Casida, JE. (1988). Metabolites of [3-13C]1,2-dibromo-3-chloropropane in male rats studied by 13C and 1H-13C correlated two-dimensional NMR spectroscopy. Biochem Pharmacol 37: 3485–3495. 10.1016/0006-2952(88)90701-0 3421999
ECHA (European Chemicals Agency). (2015). Registered substances: Perylene-3,4:9,10-tetracarboxydiimide [Database]. Helsinki, Finland. Retrieved from https://echa.europa.eu/registration-dossier/-/registered-dossier/10330
Foote, RH; Berndtson, WE; Rounsaville, TR. (1986a). Use of quantitative testicular histology to assess the effect of dibromochloropropane (DBCP) on reproduction in rabbits. Toxicol Sci 6: 638–647. 10.1016/0272-0590(86)90176-4
Foote, RH; Schermerhorn, EC; Simkin, ME. (1986b). Measurement of semen quality, fertility, and reproductive hormones to assess dibromochloropropane (DBCP) effects in live rabbits. Fundam Appl Toxicol 6: 628–637. 10.1016/0272-0590(86)90175-2 3086172
Gargas, ML; Burgess, RJ; Voisard, DE; Cason, GH; Andersen, ME. (1989). Partition coefficient of low-molecular-weight volatile chemicals in various tissues and liquids. Toxicol Appl Pharmacol 98: 87–99. 10.1016/0041-008x(89)90137-3 2929023
Gingell, R; Beatty, PW; Mitschke, HR; Page, AC; Sawin, VL; Putcha, L; Kramer, WG. (1987). Toxicokinetics of 1,2-dibromo-3-chloropropane (DBCP) in the rat. Toxicol Appl Pharmacol 91: 386–394. 10.1016/0041-008x(87)90060-3 3424372
Guengerich, FP. (1994). Metabolism and genotoxicity of dihaloalkanes [Review]. Adv Pharmacol 27: 211–236. 10.1016/S1054-3589(08)61034-0 8068554
Guengerich, FP; Peterson, LA; Cmarik, JL; Koga, N; Inskeep, PB. (1987). Activation of dihaloalkanes by glutathione conjugation and formation of DNA adducts. Environ Health Perspect 76: 15–18. 10.1289/ehp.877615 3329096
Gwinn, MR; Johns, DO; Bateson, TF; Guyton, KZ. (2011). A review of the genotoxicity of 1,2-dichloroethane (EDC) [Review]. Mutat Res 727: 42–53. 10.1016/j.mrrev.2011.01.001 21255676
Heindel, JJ; Berkowitz, AS; Kyle, G; Luthra, R; Bruckner, JV. (1989). Assessment in rats of the gonadotoxic and hepatorenal toxic potential of dibromochloropropane (DBCP) in drinking water. Fundam Appl Toxicol 13: 804–815. 10.1093/toxsci/13.4.804 2620797
Hughes, TJ; Simmons, DS; Monteith, LG; Myers, LE; Claxton, LD. (1987). Mutagenicity of 31 organic compounds in a modified preincubation ames assay with Salmonella typhimurium strains TA100 and TA102 [Abstract]. Environ Mutagen 9: 49. 10.1002/em.2860090602
Humphreys, WG; Kim, DH; Guengerich, FP. (1991). Isolation and characterization of N7-guanyl adducts derived from 1,2-dibromo-3-chloropropane. Chem Res Toxicol 4: 445–453. 10.1021/tx00022a008 1912332
IARC (International Agency for Research on Cancer). (1995). Dry cleaning, some chlorinated solvents and other industrial chemicals: Summary of data reported and evaluation. Lyon, France.
IARC (International Agency for Research on Cancer). (1999). Re-evaluation of some organic chemicals, hydrazine, and hydrogen peroxide [IARC Monograph]. In IARC monographs on the evaluation of carcinogenic risks to humans. Lyon, France. http://monographs.iarc.fr/ENG/Monographs/vol71/mono71.pdf
IARC (International Agency for Research on Cancer). (2017). 1,2-Dichloropropane. Some chemicals used as solvents and in polymer manufacture [IARC Monograph]. In IARC monographs on the evaluation of carcinogenic risks to humans (pp. 141–175). Lyon, France.
IARC (International Agency for Research on Cancer). (2018). IARC monographs on the evaluation of carcinogenic risk to humans. http://monographs.iarc.fr/ENG/Monographs/PDFs/index.php
IPCS (International Programme on Chemical Safety). (2020). INCHEM: Chemical safety information from intergovernmental organizations [Database]. Geneva, Switzerland: World Health Organization, Canadian Centre for Occupational Health and Safety. Inter-Organization Programme for the Sound Management of Chemicals. Retrieved from http://www.inchem.org/
Japan Industrial Safety and Health Association. (2005a). Summary of inhalation carcinogenicity study of 1-bromo-3-chloropropane in BDF1 mice. (Study No.0418). Ministry of Health, Labour and Welfare. Japan Bioassay Research Center. http://anzeninfo.mhlw.go.jp/user/anzen/kag/pdf/gan/1-Bromo-3-Chloropropane_Mice.pdf
Japan Industrial Safety and Health Association. (2005b). Summary of inhalation carcinogenicity study of 1-bromo-3-chloropropane in F344 rats. (Study No.0417). Ministry of Health, Labour and Welfare. Japan Bioassay Research Center. http://anzeninfo.mhlw.go.jp/user/anzen/kag/pdf/gan/1-Bromo-3-Chloropropane_Rats.pdf
Jean, PA; Reed, DJ. (1992). Utilization of glutathione during 1,2-dihaloethane metabolism in rat hepatocytes. Chem Res Toxicol 5: 386–391. 10.1021/tx00027a011 1504262
Johnston, RV; Mensik, DC; Taylor, HW; Jersey, GC; Dietz, FK. (1986). Single-generation drinking water reproduction study of 1,2-dibromo-3-chloropropane in Sprague-Dawley rats. Bull Environ Contam Toxicol 37: 531–537. 10.1007/BF01607800 3768549
Kirkland, D; Aardema, M; Henderson, L; Müller, L. (2005). Evaluation of the ability of a battery of three in vitro genotoxicity tests to discriminate rodent carcinogens and non-carcinogens: I. Sensitivity, specificity and relative predictivity. Mutat Res 584: 1–256. 10.1016/j.mrgentox.2005.02.004 15979392
Lamb, JC; Tyl, R; Lawton, AD. (1997). Reproductive toxicology. Dibromochloropropane [Abstract]. Environ Health Perspect 105 Suppl 1: 299–300.9114334
Lebaron, MJ; Hotchkiss, JA; Zhang, F; Koehler, MW; Boverhof, DR. (2021). Investigation of potential early key events and mode of action for 1,2-dichloroethane-induced mammary tumors in female rats. J Appl Toxicol 41: 362–374. 10.1002/jat.4048 32830330
Lewis, RJ, Sr; Hawley, GG. (2007). Sym-bromochloroethane. In RJ Lewis, Sr.; GG Hawley (Eds.), Hawley’s condensed chemical dictionary (15th ed., pp. 183). Hoboken, NJ: John Wiley & Sons. 10.1002/9780470114735.hawley02335
Maltoni, C; Valgimigli, L; Scarnato, C. (1980). Long-term carcinogenic bioassays on ethylene dichloride administered by inhalation to rats and mice. In B Ames; P Infante; R Reitz (Eds.), Ethylene dichloride: A potential health risk? (pp. 3–29). Cold Spring Harbor, NY: Cold Spring Harbor Laboratory.
Marchand, DH; Reed, DJ. (1989). Identification of the reactive glutathione conjugate S-(2-chloroethyl)glutathione in the bile of 1-bromo-2-chloroethane-treated rats by highpressure liquid chromatography and precolumn derivatization with o-phthalaldehyde. Chem Res Toxicol 2: 449–454. 10.1021/tx00012a015 2519736
Meistrich, ML; Wilson, G; Shuttlesworth, GA; Porter, KL. (2003). Dibromochloropropane inhibits spermatogonial development in rats. Reprod Toxicol 17: 263–271. 10.1016/S0890-6238(03)00007-8 12759094
Moody, DE; James, JL; Smuckler, EA. (1980). Cytochrome P-450 lowering effect of alkyl halides, correlation with decrease in arachidonic acid. Biochem Biophys Res Commun 97: 673–679. 10.1016/0006-291X(80)90317-4 7470119
Nagano, K; Umeda, Y; Senoh, H; Gotoh, K; Arito, H; Yamamoto, S; Matsushima, T. (2006). Carcinogenicity and chronic toxicity in rats and mice exposed by inhalation to 1,2-dichloroethane for two years. J Occup Health 48: 424–436. 10.1539/joh.48.424 17179635
NIOSH (National Institute for Occupational Safety and Health). (2018). NIOSH pocket guide to chemical hazards. Index of chemical abstracts service registry numbers (CAS No.). Atlanta, GA. http://www.cdc.gov/niosh/npg/npgdcas.html
Nitschke, KD; Kociba, RJ; Keyes, DG; McKenna, MJ. (1981). A thirteen week repeated inhalation study of ethylene dibromide in rats. Fundam Appl Toxicol 1: 437–442. 10.1016/s0272-0590(81)80024-3 6764425
NLM (National Library of Medicine). (2005). Chemical Carcinogenesis Research Information System (CCRIS). 1-Bromo-2-chloroethane. Retrieved from https://www.nlm.nih.gov/databases/download/ccris.html
NLM (National Library of Medicine). (2016). ChemIDplus advanced. 1-Bromo-2-chloroethane, CASRN: 107-04-0. Available online at https://chem.nlm.nih.gov/chemidplus/rn/startswith/107-04-0
NOAA (National Oceanic and Atmospheric Administration). (2015). CAMEO Chemicals. Version 2.4.2. 1-Chloro-2-bromoethane, CAS number 107-04-0 (Version 2.5 rev 1). Retrieved from http://m.cameochemicals.noaa.gov
NRC (National Research Council). (2014). Acute exposure guideline levels for selected airborne chemicals: Volume 17. Washington, DC: National Academies Press. 10.17226/18796
NTP (National Toxicology Program). (1978). Bioassay of dibromochloropropane for possible carcinogenicity. Natl Cancer Inst Carcinog Tech Rep Ser 28: 1–66.12844180
NTP (National Toxicology Program). (1982). Carcinogenesis bioassay of 1,2-dibromoethane (CAS no 106-93-4) in F344 rats and B6C3F1 mice (inhalation study) (pp. 1–163). https://search.proquest.com/docview/1859405604?accountid=171501
NTP (National Toxicology Program). (1990). Genetic toxicity evaluation of 1-chloro-2-bromoethane in Salmonella/E. coli mutagenicity test or Ames test study 406801. Chemical Effects in Biological Systems (CEBS). Available online at http://tools.niehs.nih.gov/cebs3/ntpViews/?studyNumber=002-01115-0001-0000-1
NTP (National Toxicology Program). (1991). NTP technical report on the toxicity studies of 1,2-dichloroethane (ethylene dichloride) in F344/N rats, Sprague Dawley rats, OsborneMendel rats, and B6C3F1 mice (drinking water and gavage Studies) (CAS No. 107-06-2). (NTP TOX 4. NIH Publication No. 91-3123). https://ntp.niehs.nih.gov/ntp/htdocs/st_rpts/tox004.pdf
NTP (National Toxicology Program). (2016a). 14th Report on carcinogens. Research Triangle Park, NC. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html
NTP (National Toxicology Program). (2016b). Report on carcinogens, 14th edition: 1,2-Dibromo-3-chloropropane. In Report on Carcinogens. Research Triangle Park, NC: U.S. Department of Health and Human Services, National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/dibromochloropropane.pdf
NTP (National Toxicology Program). (2016c). Report on carcinogens, 14th edition: 1,2-Dibromoethane. In Report on Carcinogens. Research Triangle Park, NC: U.S. Department of Health and Human Services, National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/dibromoethane.pdf
NTP (National Toxicology Program). (2016d). Report on carcinogens, 14th edition: 1,2-Dichloroethane. In Report on Carcinogens. Research Triangle Park, NC: U.S. Department of Health and Human Services, National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/dichloroethane.pdf
NTP (National Toxicology Program). (2016e). Report on carcinogens, 14th edition: 1,2,3-Trichloropropane. In Report on Carcinogens. Research Triangle Park, NC: U.S. Department of Health and Human Services, National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/trichloropropane.pdf
NTP (National Toxicology Program). (2017). NTP technical reports index. Available online at https://ntp.niehs.nih.gov/results/summaries/chronicstudies/index.html
NTP (National Toxicology Program). (2021). Testing status of 1,2-dichloroethane 10962-L. Available online at https://ntp.niehs.nih.gov/go/ts-10962-l
Oda, Y; Yamazaki, H; Thier, R; Ketterer, B; Guengerich, FP; Shimada, T. (1996). A new Salmonella typhimurium NM5004 strain expressing rat glutathione S-transferase 5-5: Use in detection of genotoxicity of dihaloalkanes using an SOS/umu test system. Carcinogenesis 17: 297–302. 10.1093/carcin/17.2.297 8625454
OECD (Organisation for Economic Co-operation and Development). (2018). The OECD QSAR toolbox for grouping chemicals into categories. Retrieved from https://www.qsartoolbox.org/
Omichinski, JG; Brunborg, G; Holme, JA; Søderlund, EJ; Nelson, SD; Dybing, E. (1988a). The role of oxidative and conjugative pathways in the activation of 1,2-dibromo-3chloropropane to DNA-damaging products in rat testicular cells. Mol Pharmacol 34: 74–79.3393142
Omichinski, JG; Søderlund, EJ; Dybing, E; Pearson, PG; Nelson, SD. (1988b). Detection and mechanism of formation of the potent direct-acting mutagen 2-bromoacrolein from 1,2-dibromo-3-chloropropane. Toxicol Appl Pharmacol 92: 286–294.3277317
OSHA (Occupational Safety & Health Administration). (2020a). Air contaminants: Occupational safety and health standards for shipyard employment, subpart Z, toxic and hazardous substances. (OSHA Standard 1915.1000). Washington, DC. https://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10286
OSHA (Occupational Safety & Health Administration). (2020b). Table Z-1: Limits for air contaminants. Occupational safety and health standards, subpart Z, toxic and hazardous substances. Available online at http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=9992
Pearson, PG; Omichinski, JG; Myers, TG; Søderlund, EJ; Dybing, E; Nelson, SD. (1990). Metabolic activation of 1,2-dibromo-3-chloropropane to mutagenic metabolites: detection and mechanism of formation of (Z)- and (E)-2-chloro-3-(bromomethyl)oxirane. Chem Res Toxicol 3: 458–466.2133097
Rao, KS; Burek, JD; Murray, FJ; John, JA; Schwetz, BA; Bell, TJ; Potts, WJ; Parker, CM. (1983). Toxicologic and reproductive effects of inhaled 1,2-dibromo-3-chloropropane in rats. Toxicol Sci 3: 104–110110. 10.1016/S0272-0590(83)80064-5
Rao, KS; Burek, JD; Murray, FJ; John, JA; Schwetz, BA; Beyer, JE; Parker, CM. (1982). Toxicologic and reproductive effects of inhaled 1,2-dibromo-3-chloropropane in male rabbits. Toxicol Sci 2: 241–251.
Rao, KS; Murray, JS; Deacon, MM; John, JA; Calhoun, LL; Young, JT. (1980). Teratogenicity and reproduction studies in animals inhaling ethylene dichloride. In B Ames; P Infante; R Reitz (Eds.), Banbury Report, Vol 5 Ethylene Dichloride: A Potential Health Risk (pp. P149–P166). Cold Spring Harbor, NY: Cold Spring Harbor Laboratory.
Reel, JR; Wolkowski-Tyl, R; Lawton, AD. (1984). Dibromochloropropane: reproduction and fertility assessment in CD-1 mice when administered by gavage. Reel, JR; Wolkowski-Tyl, R; Lawton, AD.
Reitz, RH; Fox, TR; Ramsey, JC; Quast, JF; Langvardt, PW; Watanabe, PG. (1982). Pharmacokinetics and macromolecular interactions of ethylene dichloride in rats after inhalation or gavage. Toxicol Appl Pharmacol 62: 190–204. 10.1016/0041-008X(82)90117-X 7058523
Reznik, G; Reznik-Schuller, H; Ward, JM; Stinson, SF. (1980a). Morphology of nasal-cavity tumours in rats after chronic inhalation of 1,2-dibromo-3-chloropropane. Br J Cancer 42: 772–781. 10.1038/bjc.1980.311 7459212
Reznik, G; Stinson, SF; Ward, JM. (1980b). Lung tumors induced by chronic inhalation of 1,2-dibromo-3-chloropropane in B6C3F1 mice. Cancer Lett 10: 339–342. 10.1016/0304-3835(80)90051-8 6253052
Reznik, G; Stinson, SF; Ward, JM. (1980c). Respiratory pathology in rats and mice after inhalation of 1,2-dibromo-3-chloropropane or 1,2 dibromoethane for 13 weeks. Arch Toxicol 46: 233–240. 10.1007/BF00310439 7016076
Shimada, T; Yamazaki, H; Oda, Y; Hiratsuka, A; Watabe, T; Guengerich, FP. (1996). Activation and inactivation of carcinogenic dihaloalkanes and other compounds by glutathione S-transferase 5-5 in Salmonella typhimurium tester strain NM5004. Chem Res Toxicol 9: 333–340. 10.1021/tx950125v 8924613
Short, RD; Winston, JM; Hong, CB; Minor, JL; Lee, CC; Seifter, J. (1979). Effects of ethylene dibromide on reproduction in male and female rats. Toxicol Appl Pharmacol 49: 97–105. 10.1016/0041-008X(79)90281-3 382441
Søderlund, EJ; Brunborg, G; Omichinski, JG; Holme, JA; Dahl, JE; Nelson, SD; Dybing, E. (1988). Testicular necrosis and DNA damage caused by deuterated and methylated analogs of 1,2-dibromo-3-chloropropane in the rat. Toxicol Appl Pharmacol 94: 437–447. 10.1016/0041-008X(88)90284-0 3400095
Spencer, HC; Rowe, VK; Adams, EM; McCollister, DD; Irish, DD. (1951). Vapor toxicity of ethylene dichloride determined by experiments on laboratory animals. Arch Ind Hyg Occup Med 4: 482–493.
Spreafico, F; Zuccato, E; Marcucci, F; Sironi, M; Paglialunga, S; Madonna, M; Mussini, E. (1980). Pharmacokinetics of ethylene dichloride in rats treated by different routes and its long-term inhalatory toxicity. In B Ames; P Infante; R Reitz (Eds.), Ethylene dichloride: A potential health risk? (Banbury Report 5 ed., pp. 107–133). Cold Spring Harbor, NY: Cold Spring Harbor Laboratory.
Stinson, SF; Reznik, G; Ward, JM. (1981). Characteristics of proliferative lesions in the nasal cavities of mice following chronic inhalation of 1,2-dibromoethane. Cancer Lett 12: 121–129. 10.1016/0304-3835(81)90047-1 7023670
Storer, RD; Conolly, RB. (1983). Comparative in vivo genotoxicity and acute hepatotoxicity of three 1,2-dihaloethanes. Carcinogenesis 4: 1491–1494. 10.1093/carcin/4.11.1491 6357525
Tan, EL; Hsie, AW. (1981). Mutagenicity and cytotoxicity of haloethanes as studied in the CHO/HGPRT system. Mutat Res 90: 183–191. 10.1016/0165-1218(81)90081-1 7035935
U.S. EPA (U.S. Environmental Protection Agency). (1985). Health and environmental effects profile for bromochloroethanes [EPA Report]. (EPA/600/X-85/391). Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development.
U.S. EPA (U.S. Environmental Protection Agency). (1986). Guidelines for carcinogen risk assessment [EPA Report] (pp. 33993–34003). (EPA/630/R-00/004). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/iris/basic-information-about-integrated-risk-information-system#risk
U.S. EPA (U.S. Environmental Protection Agency). (1988). Recommendations for and documentation of biological values for use in risk assessment [EPA Report]. (EPA/600/6-87/008). Cincinnati, OH. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=34855
U.S. EPA (U.S. Environmental Protection Agency). (1993). Integrated Risk Information System (IRIS) chemical assessment summary for 1,2-dichloroethane (CASRN 107-06-2). https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0149_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1994). Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry [EPA Report]. (EPA/600/8-90/066F). Research Triangle Park, NC. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=71993&CFID=51174829&CFTOKEN=25006317
U.S. EPA (U.S. Environmental Protection Agency). (2002). A review of the reference dose and reference concentration processes. (EPA/630/P-02/002F). Washington, DC. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2003). Integrated Risk Information System (IRIS) chemical assessment summary for 1,2-dibromo-3-chloropropane (DBCP); CASRN 96-12-8. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0414_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2004). Toxicological review of 1,2-dibromoethane (CASRN 106-93-4) in support of summary information on the Integrated Risk Information System (IRIS) [EPA Report]. (EPA/635/R-04/067). Washington, DC. https://iris.epa.gov/static/pdfs/0361tr.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2005). Guidelines for carcinogen risk assessment [EPA Report]. (EPA/630/P-03/001F). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3-25-05.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2006). Provisional peer-reviewed toxicity values for 1,2-dibromo-3-chloropropane (CASRN 96-12-8) [EPA Report]. Cincinnati, OH. http://hhpprtv.ornl.gov/issue_papers/Dibromo3Chloropropane12.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009). Toxicological review of 1,2,3-trichloropropane (CASRN 96-18-4): In support of summary information on the Integrated Risk Information System (IRIS) [EPA Report] (pp. 247). (EPA/635/R-08/010F). Washington, DC. https://iris.epa.gov/static/pdfs/0200tr.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2010). Provisional peer-reviewed toxicity values for 1,2-dichloroethane (CASRN 107-06-2) [EPA Report]. Cincinnati, OH. http://hhpprtv.ornl.gov/issue_papers/Dichloroethane12.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2011a). Chemical Assessment Clustering Engine (ChemACE) [Database]. Retrieved from https://www.epa.gov/tsca-screening-tools/chemical-assessment-clustering-engine-chemace
U.S. EPA (U.S. Environmental Protection Agency). (2011b). Health effects assessment summary tables (HEAST) for superfund. Available online at https://epa-heast.ornl.gov/heast.php
U.S. EPA (U.S. Environmental Protection Agency). (2011c). Recommended use of body weight 3/4 as the default method in derivation of the oral reference dose. (EPA/100/R-11/0001). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/recommended-use-of-bw34.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2012). Estimation Programs Interface Suite™ for Microsoft® Windows, v 4.11: 1 Bromo-2-chloroethane (CASRN 107-04-0) [Fact Sheet]. Washington, DC. https://www.epa.gov/tsca-screening-tools/epi-suitetm-estimation-program-interface
U.S. EPA (U.S. Environmental Protection Agency). (2015a). About the TSCA chemical substance inventory. Download the non-confidential TSCA inventory [Database]. Retrieved from http://www2.epa.gov/tsca-inventory/how-access-tsca-inventory
U.S. EPA (U.S. Environmental Protection Agency). (2015b). Bromochloroethane. ChemView [Computer Program]. Retrieved from https://java.epa.gov/chemview#dashboard
U.S. EPA (U.S. Environmental Protection Agency). (2015c). Significant New Use Rules (SNUR). Reviewing new chemicals under the Toxic Substances Control Act (TSCA). http://www.epa.gov/reviewing-new-chemicals-under-toxic-substances-control-act-tsca/epa-actions-reduce-risk-new#SNURs
U.S. EPA (U.S. Environmental Protection Agency). (2017). IRIS carcinogens: §69502.2(a)(1)(E). Chemicals that are identified as “carcinogenic to humans,” “likely to be carcinogenic to humans,” or Group A, B1, or B2 carcinogens in the United States Environmental Protection Agency’s Integrated Risk Information System. Available online
U.S. EPA (U.S. Environmental Protection Agency). (2018). Integrated Risk Information System. IRIS Assessments. Washington, DC. Retrieved from http://www.epa.gov/iris/
U.S. EPA (U.S. Environmental Protection Agency). (2020a). CompTox Chemicals Dashboard: 1,2-Dibromoethane [Database]. Washington, DC. Retrieved from https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID3020415#toxicity-values
U.S. EPA (U.S. Environmental Protection Agency). (2020b). CompTox Chemicals Dashboard: 1,2-Dichloroethane [Database]. Retrieved from https://comptox.epa.gov/dashboard/dsstoxdb/results?search=1,2-dichloroethane#toxicity-values
U.S. EPA (U.S. Environmental Protection Agency). (2020c). Integrated risk information system. IRIS assessments [Database]. Washington, DC. Retrieved from http://www.epa.gov/iris/
U.S. EPA (U.S. Environmental Protection Agency). (2020d). Provisional peer-reviewed toxicity values (PPRTVs) for superfund: Derivation support documents [Database]. Washington, DC. Retrieved from https://www.epa.gov/pprtv
van Beerendonk, GJ; van Gog, FB; Vrieling, H; Pearson, PG; Nelson, SD; Meerman, JH. (1994). Blocking of in vitro DNA replication by deoxycytidine adducts of the mutagen and clastogen 2-bromoacrolein. Cancer Res 54: 679–684.8306329
van Bladeren, PJ; Breimer, DD; Rotteveel-Smijs, GM; de Knijff, P; Mohn, GR; van Meeteren-Wälchli, B; Buijs, W; van der Gen, A. (1981). The relation between the structure of vicinal dihalogen compounds and their mutagenic activation via conjugation to glutathione. Carcinogenesis 2: 499–505.7273330
Van Esch, G; Kroes, R; Van Logten, M; Den Tonkelaar, E. (1977). Ninety-day toxicity study with 1,2-dichloroethane (DCE) in rats. (Report 195/77 Alg.Tox). Bilthoven, the Netherlands: National Institute of Public Health and Environmental Protection.
Wang, NC; Zhao, QJ; Wesselkamper, SC; Lambert, JC; Petersen, D; Hess-Wilson, JK. (2012). Application of computational toxicological approaches in human health risk assessment. I. A tiered surrogate approach. Regul Toxicol Pharmacol 63: 10–19. 10.1016/j.yrtph.2012.02.006 22369873
Wheeler, JB; Stourman, NV; Armstrong, RN; Guengerich, FP. (2001). Conjugation of haloalkanes by bacterial and mammalian glutathione transferases: mono- and vicinal dihalothanes. Chem Res Toxicol 14: 1107–1117. 10.1021/tx0100183 11511185