# APPENDIX C RESULTS OF THE SCREENING EVALUATION OF POTENTIAL CARCINOGENICITY

## STEP 1 USE OF AUTOMATED TOOLS TO IDENTIFY STRUCTURAL ANALOGUES WITH CARCINOGENICITY AND/OR GENOTOXICITY DATA

U.S. EPA’s Chemical Assessment Clustering Engine (ChemACE) clustering was performed as described in Appendix B. Using the most restrictive clustering rules (where ChemACE assigns a unique definition for each fragment, ensuring that each chemical submitted for clustering appears in only one ChemACE cluster), 1-bromo-2-chloroethane appeared in Cluster 67, which did not contain any other compounds. Using the less restrictive clustering option, ChemACE treats adjacent halogens as equivalent fragments, resulting in the inclusion of 1-bromo-2-chloroethane in multiple clusters. Using the more permissive fragment definition, halogens (i.e., bromine [Br] and chlorine [Cl]) in the structures could be swapped in the clustering scheme and appear in more than one cluster. Five clusters (15, 31, 34, 49, and 152) contain 1-bromo-2-chloroethane and a total of 38 other halogenated chemicals (see Table C-1 below). All of these clusters contain halogenated alkanes with chain lengths of 1−3 carbon atoms and 1−6 halogen substituents.

Table C-1 Clusters Containing 1-Bromo-2-Chloroethane (CASRN 107-04-0) and the Associated Fragments

Cluster | Fragments
15 | Cl-R or F-R or Br-R
31 | Cl-R or F-R or Br-R (but not Br-R only structures)
34 | Cl-R or F-R or Br-R (but not F-R only structures)
49 | Cl-R or F-R or Br-R or I-R
152 | Cl-R or F-R or Br-R (but not Br-R or F-R only structures)

Br = bromine; Cl = chlorine; F = fluorine; I = iodine; R = functional group (must be an aliphatic carbon attachment).

The Organisation for Economic Co-operation and Development (OECD) Quantitative Structure-Activity Relationship (QSAR) Toolbox Profiler was used to identify structural analogues from the Dice analogue search with carcinogenicity and/or genotoxicity data (see Step 1 methods in Appendix B). Only one analogue was identified in the Dice analogue search (1-bromo-3-chloropropane); this compound was also identified by ChemACE. Refinement of selection of final analogues is described below.

## STEP 2 ANALOGUE REFINEMENT USING EXPERT JUDGMENT

Expert judgment was applied to refine the initial list of 38 potential analogues based on physicochemical properties; absorption, distribution, metabolism, and excretion (ADME); and mechanisms of toxicity.

1-Bromo-2-chloroethane contains two halogen substituents with the following attributes: (1) they are labile (easily displaced) leaving groups that can undergo nucleophilic substitution; (2) they are attached to adjacent carbon atoms (1,2-substitution pattern); and (3) they are both attached at primary carbon atoms (R-CH_2_-X). Each of these attributes influences the reactivity of the molecule, its available metabolic pathways, and its potential bioactivity. Therefore, compounds were considered potential analogues if they contain (1) two or more labile halogen substituents; (2) halogens attached to adjacent, primary carbon atoms; and (3) no more than one halogen per carbon atom.

Of the 38 chemicals identified as potential analogues by ChemACE clustering and the OECD Toolbox analogue selection tool (Dice), 32 were not selected for further review, including halogenated methanes, monohalogenated compounds, and compounds with more than one halogen per carbon atom. Each of these attributes introduce significant differences in bioavailability, reactivity, and applicable metabolic pathways relative to 1-bromo-2-chloroethane.

The remaining six possible analogues for 1-bromo-2-chloroethane are listed in Table C-2. The existence of a cancer risk estimate and/or a weight-of-evidence (WOE) determination for cancer is indicated for each analogue. All of the potential analogues were included in each of the five clusters, except for 1,2-dibromoethane, which was excluded from Clusters 31 and 152.

Table C-2 Summary of Cancer Assessment Information for Analogues of 1-Bromo-2-Chloroethane (CASRN 107-04-0)^a^

Analogue Name (CASRN) | Cancer Risk Estimates (if available) | WOE Determinations
1,2-Dibromoethane (106-93-4)^b^ | U.S. EPA (2004)—OSF, IUR; CalEPA (2011)—OSF, IUR | U.S. EPA (2004)—likely; IARC (1999)—probably (Group 2A); NTP (2016c)—reasonably anticipated; CalEPA (2018)—known
1,2-Dichloroethane (107-06-2)^b^ | U.S. EPA (1993)—OSF, IUR; CalEPA (1999b)—OSF | U.S. EPA (1993)—probable; IARC (1999)—possibly (Group 2B); NTP (2016d)—reasonably anticipated; CalEPA (2018)—known
1-Bromo-3-chloropropane (109-70-6)^b,^ ^c^ | None^d^ | None
1,2-Dichloropropane (78-87-5)^b^ | U.S. EPA (2020c)—p-OSF, p-IUR; CalEPA (2004); CalEPA (1999b)—OSF | U.S. EPA (2020c)—likely; IARC (2017)—carcinogenic (Group 1); CalEPA (2018)—known
1,2-Dibromo-3-chloropropane (96-12-8)^b^ | U.S. EPA (2006)—p-OSF, p-IUR; CalEPA (2020)—OSF, IUR | U.S. EPA (2006)—likely; IARC (1999)—possibly (Group 2B); NTP (2016b)—reasonably anticipated; CalEPA (2018)—known
1,2,3-Trichloropropane (96-18-4)^b^ | U.S. EPA (2009)—OSF; CalEPA (2009)—OSF | U.S. EPA (2009)—likely; IARC (1995)—probably (Group 2A); NTP (2016b)—reasonably anticipated; CalEPA (2018)—known

a Gray shading indicates that there was not a cancer risk estimate and/or a WOE determination for cancer for that analogue.

b Found by ChemACE.

c Found by Dice.

d No cancer toxicity values are available; however, a 2-year inhalation bioassay in rats and mice with clear evidence of carcinogenicity is available from the Japanese Industrial Safety and Health Association (Japan Industrial Safety and Health Association, 2005a, b).

ChemACE = Chemical Assessment Clustering Engine; IUR = inhalation unit risk; OSF = oral slope factor; p-IUR = provisional inhalation unit risk; p-OSF = provisional oral slope factor; WOE = weight of evidence.

1-Bromo-3-chloropropane, which lacks a cancer risk estimate or a WOE determination for cancer (highlighted in gray in Table C-2), was not further considered as a potential analogue for the screening evaluation of potential carcinogenicity of 1-bromo-2-chloroethane. Compounds selected for further consideration were 1,2-dibromoethane (1,2-DBE), 1,2-dichloroethane (1,2-DCE), 1,2-dichloropropane (1,2-DCP), 1,2-dibromo-3-chloropropane (1,2-DB-3-CP), and 1,2,3-trichloropropane (TCP).

## STEP 3 COMPARISON OF THE EXPERIMENTAL GENOTOXICITY DATA FOR 1-BROMO-2-CHLOROETHANE AND ANALOGUES

The genotoxicity data available for 1-bromo-2-chloroethane are described in the “Other Data” section in the main body of this report. Available data indicate that 1-bromo-2-chloroethane and/or its metabolites display genotoxic, mutagenic, clastogenic, and deoxyribonucleic acid (DNA)-damaging activity. Genotoxicity data for the analogue compounds have been extensively reviewed. A summary of the genotoxicity data for analogue halogenated alkanes is provided in Table C-3. Overall data indicate that these analogues are mutagenic and clastogenic, and capable of binding DNA and causing DNA damage.

Table C-3 Comparison of Available Genotoxicity Data for 1-Bromo-2-Chloroethane (CASRN 107-04-0) and Candidate Analogues

Parameter | 1-Bromo-2-Chloroethane CASRN 107-04-0 | 1,2-Dibromoethane CASRN 106-93-4 | 1,2-Dichloroethane CASRN 107-06-2 | 1,2-Dichloropropane CASRN 78-87-5 | 1,2-Dibromo-3-Chloropropane CASRN 96-12-8 | 1,2,3-Trichloropropane CASRN 96-18-4
Mutagenicity | - Mutagenic in Salmonella typhimurium; - Mutagenic in mammalian cells in vitro | - Mutagenic in S. typhimurium and Streptomyces coelicolor; mixed results in Escherichia coli; - Mutagenic in Aspergillus nidulans; - Induced somatic and sex-linked recessive mutations in Drosophila melanogaster; - Mutagenic in mammalian cells in vitro; - Did not induce dominant lethal mutations in mice | - Mutagenic in S. typhimurium; mixed results in E. coli; not mutagenic in S. coelicolor or Bacillus subtilis; - Not mutagenic in A. nidulans; - Induced somatic and sex-linked recessive mutations; - Mutagenic in mammalian cells in vitro; - Induced somatic mutations in mice; - Did not induce dominant lethal mutations in mice | - Mixed results in S. typhimurium; not mutagenic in E. coli or S. coelicolor; - Mutagenic in A. nidulans; - Induced somatic mutations in D. melanogaster, but not sex-linked recessive mutations; - Mutagenic in mammalian cells in vitro; - Did not induce dominant lethal mutations in rats; - Did not induce Pig-a or Gpt mutations in mice | - Mutagenic in S. typhimurium with and without metabolic activation; - Induced sex-linked recessive mutations in D. melanogaster; - Mutagenic in mammalian cells with and without metabolic activation; - Induced somatic mutations in mice (spot test); - Induced dominant lethal mutations in rats, but not mice | - Mutagenic in S. typhimurium with metabolic activation; not mutagenic in E. coli; - Not mutagenic in A. nidulans; - Induced somatic mutations in D. melanogaster; - Mutagenic in mammalian cells with metabolic activation; - Did not induce dominant lethal mutations in rats
Clastogenicity | - Induced CAs in mammalian cells in vitro; - Induced mitotic malsegregation/aneuploidy in A. nidulans; - Induced mitotic recombination in D. melanogaster | - Induced SCEs in mammalian cells in vitro and in vivo; - Induced CAs and MNs in mammalian cells in vitro, but not in vivo | - Induced SCEs in mammalian cells in vivo; - Induced MNs in mammalian cells in vitro; - Induced chromosomal loss and mitotic recombination in D. melanogaster; - Induced aneuploidy and mitotic segregation aberrations in A. nidulans; no clear evidence of aneuploidy in mammalian cells in vitro | - Induced CAs and SCEs in mammalian cells in vitro; - Did not induce MNs in mammalian cells in vivo; - Induced mitotic recombination in D. melanogaster, but not Saccharomyces cerevisiae; - Did not induce chromosomal abnormalities in A. nidulans | - Induced CAs in mammalian cells in vitro and in vivo; - Induced MNs in mammalian cells in vivo; - Induced SCEs in mammalian cells in vitro; - Induced heritable translocation and mitotic recombination in D. melanogaster | - Induced polyploidy in mammalian cells in vivo; - Induced MNs in mammalian cells in vitro, but not in vivo; - Induced CAs and SCEs in mammalian cells in vitro; - Induced MN without metabolic activation; - Induced mitotic gene conversion in S. cerevisiae; - Did not induce chromosomal abnormalities in A. nidulans
DNA damage and adducts | - Induced DNA damage in mammalian cells in vivo; - Induced DNA damage in S. typhimurium | - Induced DNA damage/repair in mammalian cells in vitro and in vivo; - Forms DNA adducts | - Induced DNA damage/repair in mammalian cells in vitro and in vivo; - Equivocal DNA damage detected via comet assay in rodent liver cells.; - Forms DNA adducts | - Induced DNA damage/repair in mammalian cells in vitro and in vivo | - Induced DNA damage/repair in mammalian cells in vitro and in vivo; - Forms DNA adducts | - Induced DNA damage/repair in mammalian cells in vitro and in vivo; - Forms DNA adducts
Cell transformation | ND | - Induced neoplastic transformation in mammalian cells | - Mixed results for cell transformation | ND | - Induced neoplastic transformation in mammalian cells | - Induced neoplastic transformation in mammalian cells
References | See “Genotoxicity” section in main document for references | U.S. EPA (2004); IARC (1999) | Gwinn et al. (2011); ATSDR (2001); CalEPA (1999a); IARC (1999); U.S. EPA (1993); Lebaron et al. (2021) | IARC (2017); U.S. EPA (2020c); CalEPA (1999b) | U.S. EPA (2006); Clark and Snedeker (2005); IARC (1999) | U.S. EPA (2009); IARC (1995)

CA = chromosomal aberration; DNA = deoxyribonucleic acid; MN = micronuclei; ND = no data; SCE = sister chromatid exchange.

## STEP 4 TOXICOKINETICS OF 1-BROMO-2-CHLOROETHANE AND ANALOGUES

The toxicokinetics of 1-bromo-2-chloroethane and potential analogues are briefly described in Table C-4. Each of the candidate analogue compounds is metabolized by a CYP450 oxidation pathway and a direct glutathione (GSH) conjugation pathway (U.S. EPA, 2020c; IARC, 2017; CalEPA, 2009; U.S. EPA, 2009, 2006, 2004; ATSDR, 2001; IARC, 1999, 1995). Contributions from both pathways are presumed by analogy for 1-bromo-2-chloroethane as well, although experimental data for the target compound are available for the GSH conjugation pathway only (Jean and Reed, 1992; Marchand and Reed, 1989).

Experimental data show that GSH conjugation leads to the formation of episulfonium ions via cyclization of GSH adducts for 1,2-DBE, 1,2-DCE, 1,2-DB-3-CP, and TCP (CalEPA, 2009; U.S. EPA, 2009, 2004; ATSDR, 2001; IARC, 1995; Guengerich, 1994; van Beerendonk et al., 1994; Dekant and Vamvakas, 1993; Pearson et al., 1990; Dohn et al., 1988; Omichinski et al., 1988b; Omichinski et al., 1988a; Guengerich et al., 1987). Based on analogy and identified glutathione-conjugated metabolites, episulfonium ion generation is also expected following GSH conjugation of 1-bromo-2-chloroethane (based on formation of S-[2-chloroethyl]glutathione [CEG]) (Jean and Reed, 1992; Marchand and Reed, 1989) and 1,2-DCP (based on the formation of S-[2-hydroxypropyl]glutathione) (IARC, 2017).

No data are available for absorption, distribution, or excretion of 1-bromo-2-chloroethane. Experimental data indicate that all candidate analogues show rapid and extensive absorption, wide distribution, and primary excretion in urine (U.S. EPA, 2020c; IARC, 2017; CalEPA, 2009; U.S. EPA, 2009, 2006, 2004; ATSDR, 2001; IARC, 1999, 1995).

Table C-4 Summary of Toxicokinetic Data for 1-Bromo-2-Chloroethane and Analogues

Compound (CASRN) | Absorption, Distribution, Excretion | Metabolism | References
1-Bromo-2-chloroethane (107-04-0) | ND | Primary metabolic pathways are oxidation by CYP450 (by analogy to other dihaloalkanes) and GSH conjugation (demonstrated); 1. Primary metabolites formed via oxidation expected to be:; - 2-bromoacetaldehyde; - 2-chloroacetaldehyde; - HBr; - HCl; 2. Primary metabolites formed via GSH conjugation:; - CEG, with HBr release (minor HCl release); - Inferred from other dihaloalkanes: CEG will cyclize to form episulfonium ion | Guengerich (1994); Dekant and Vamvakas (1993); Jean and Reed (1992); Gargas et al. (1989); Marchand and Reed (1989); Guengerich et al. (1987)
1,2-Dibromoethane (106-93-4) | - Rapid and extensive absorption (oral and inhalation); - Wide distribution; - Primary excretion in urine, small amounts in feces and exhaled air | Primary metabolic pathways are oxidation by CYP450 and GSH conjugation; 1. Primary metabolites formed via oxidation:; - 2-bromoacetaldehyde; - HBr; 2. Primary metabolites formed via GSH conjugation:; - BEG, with HBr release; - Episulfonium ion (from cyclization of GSH adduct in BEG) | U.S. EPA (2004); Gargas et al. (1989); Guengerich et al. (1987)
1,2-Dichloroethane (107-06-2) | - Rapid and extensive absorption (oral and inhalation); - Wide distribution; - Primary excretion in urine, small amounts in feces and exhaled air | Primary metabolic pathways are oxidation by CYP450 and GSH conjugation; 1. Primary metabolites formed via oxidation:; - 2-chloroacetaldehyde; - HCl; 2. Primary metabolites formed via GSH conjugation:; - CEG, with HCl release; - Episulfonium ion (from cyclization of GSH adduct in CEG) | ATSDR (2001); Gargas et al. (1989); Guengerich et al. (1987)
1,2-Dichloropropane (78-87-5) | - Readily absorbed (oral, inhalation, dermal); - Wide distribution, with preferential disposition in body fat at high exposures; - Rapid elimination, primarily via urine with small amounts via exhaled breath (proportion increases with increased exposure) | Primary metabolic pathway is oxidation by CYP2E1 followed by GSH conjugation (or vice versa) to form:; - S-(2-oxopropyl)glutathione (identified); - S-(1-carboxyethyl)glutathione (identified); - S-(2-hydroxypropyl)glutathione (presumed based on cysteine-conjugated urinary metabolite); Presumed secondary pathways (based on identified metabolites and known metabolism of similar haloalkanes); - Formation of episulfonium ions from cyclization of GSH adduct in S-(2-hydroxypropyl)glutathione; - Oxidative dechlorination, leading to formation of lactate and release of carbon dioxide | IARC (2017); U.S. EPA (2020c)
1,2-Dibromo-3-chloropropane (96-12-8) | - Rapid and extensive absorption (oral; no inhalation data); - Wide distribution; - Most excretion in urine, some in exhaled air, small amounts in feces | Primary metabolic pathways are oxidation by CYP450 and GSH conjugation; 1. Primary metabolites formed via oxidation:; - 2-chloro-3-(bromomethyl)oxirane; - 1-bromo-3-chloroacetone; - HBr; - HCl; 2. Primary metabolites formed via GSH conjugation:; - CBPG, with HBr release (minor HCl release); - Episulfonium ion (from cyclization of GSH adduct in CBPG) | Guengerich (1994); van Beerendonk et al. (1994); Dekant and Vamvakas (1993); Humphreys et al. (1991); Pearson et al. (1990); Dohn et al. (1988); Omichinski et al. (1988a); Omichinski et al. (1988b); Gingell et al. (1987); Guengerich et al. (1987)
1,2,3-Trichloropropane (96-18-4) | - Rapid and extensive absorption (oral; no inhalation data); - Rapid distribution, initially to adipose tissue, liver, and kidney; - Primary excretion in urine, smaller amounts in feces and exhaled air | Primary metabolic pathways are oxidation by CYP450 and GSH conjugation; 1. Primary metabolites formed via oxidation:; - 1,3-dichloroacetone; - 2,3-dichloropropanal; - Chloroacrolein; - HCl; 2. Primary metabolites formed via GSH conjugation:; - Β-chlorothioether with HCl release; - Episulfonium ion (from cyclization of GSH adduct in thioether) | CalEPA (2009); U.S. EPA (2009); IARC (1995)

BEG = S-(2-bromoethyl)glutathione; CBPG = S-(3-chloro-2-bromopropyl) glutathione; CEG = S-(2-chloroethyl)glutathione; CYP450 = cytochrome P450; GSH = glutathione; HBr = hydrogen bromide; HCl = hydrogen chloride; ND = no data.

## STEP 5 CARCINOGENICITY OF 1-BROMO-2-CHLOROETHANE ANALOGUES AND MODE-OF-ACTION DISCUSSION

U.S. EPA cancer WOE descriptors for 1-bromo-2-chloroethane and analogue compounds are shown in Tables C-5 (oral) and C-6 (inhalation). As noted in the PPRTV document, there is “Inadequate Information to Assess the Carcinogenic Potential” of 1-bromo-2-chloroethane. All analogues are characterized as having evidence of carcinogenic potential. 1,2-DBE, 1,2-DCP, 1,2-DB-3-CP, and TCP were all classified as “Likely to be Carcinogenic to Humans” (U.S. EPA, 2020c, 2009, 2006, 2004) under the 2005 or 1999 Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005). 1,2-DCE is considered a “Probable Human Carcinogen” (U.S. EPA, 1993) under the 1986 Guidelines for Carcinogen Risk Assessment (U.S. EPA, 1986). OSF values varied by several orders of magnitude, with the highest potency value calculated for TCP and the lowest (provisional) potency value for 1,2-DCP. IUR values also varied by several orders of magnitude, with the highest potency value calculated for 1,2-DB-3-CP (provisional) and the lowest potency value for 1,2-DCP (provisional).

Several epidemiology studies in print shop workers in Japan reported a potential correlation between exposure to 1,2-DCP (and other solvents) and cholangiocarcinoma, a rare cancer of the bile duct (U.S. EPA, 2020c; IARC, 2017). However, the population size is small in most of these studies, and the workers were exposed to numerous other solvents, including dichloromethane and 1,1,1-trichloroethane, as well as kerosene and printing ink, confounding interpretation of the results. Some human epidemiology studies for 1,2-DCE, 1,2-DBE, and 1,2-DB-3-CP have found limited evidence of increased risk of certain cancers (e.g., lymphatic, hematopoietic, pancreatic, and stomach cancer); however, due to multiple exposures in the available studies, these data are inadequate to evaluate a relationship between human cancer and exposure to a specific compound (NTP, 2016b, c, d; U.S. EPA, 2006, 2004; IARC, 1999). No human cancer data are available for TCP (NTP, 2016e; U.S. EPA, 2009).

All analogues are associated with tumor induction in animal bioassays (U.S. EPA, 2020c; IARC, 2017; NTP, 2016b, c, d, e; U.S. EPA, 2006, 2004; IARC, 1999, 1995; U.S. EPA, 1993). These are briefly summarized below and in Table C-5 (oral) and Table C-6 (inhalation).

Common target organs and systems in rats and/or mice following exposure to analogues include the liver, respiratory system, and mammary gland. All analogues induced hepatocellular neoplasms (adenomas and/or carcinomas) following chronic oral exposure; liver tumors were also increased following chronic inhalation exposure to 1,2-DCE. All analogues tested via the inhalation route also induced respiratory tract tumors, including nasal cavity tumors (1,2-DBE, 1,2-DCP, 1,2-DB-3-CP) and lung tumors (1,2-DBE, 1,2-DCE, 1,2-DCP, 1,2-DB-3-CP). Lung tumors were also observed following oral exposure to 1,2-DBE and 1,2-DCE. Mammary gland tumors were increased following exposure to analogues via the oral route (1,2-DCE, 1,2-DCP, 1,2-DB-3-CP, TCP) and/or the inhalation route (1,2-DBE, 1,2-DCE, 1,2-DB-3-CP).

The gastrointestinal, endocrine, and circulatory systems were also identified as cancer targets for the majority of analogues. Most analogues induced tumors of the gastrointestinal system following chronic oral exposure, including forestomach tumors (1,2-DBE, 1,2-DCE, 1,2-DB-3-CP, TCP); tongue, pharynx, and stomach tumors (1,2-DB-3-CP); oral cavity and alimentary system tumors (TCP); and esophageal papillomas (1,2-DBE). Endocrine tumors observed included thyroid tumors (1,2-DBE, 1,2-DCP) and pancreatic tumors (TCP) following oral exposure and adrenal tumors (1,2-DBE and 1,2-DB-3-CP) following inhalation exposure. Hemangiosarcoma, most notably in the spleen, was observed following oral or inhalation exposure to 1,2-DBE, oral exposure to 1,2-DCE, and inhalation exposure to 1,2-DCP.

Other tumor types were identified in only one or two of the analogues and therefore do not represent common targets of the identified analogue chemicals (see Tables C-5 and C-6 for more details). Observed tumors included female reproductive tumors (1,2-DCE, TCP), renal tumors (TCP, 1,2-DB-3-CP), malignant lymphoma (1,2-DCE), Harderian gland tumors (TCP, 1,2-DCP), Zymbal gland tumors (TCP), preputial gland tumors (TCP), mesothelioma of the peritoneum (1,2-DCE), mesothelioma of the tunica vaginalis (1,2-DBA, 1,2-DB-3-CP), and subcutaneous tumors (1,2-DBE, 1,2-DCE).

U.S. EPA (2009) and U.S. EPA (2006) concluded that 1,2-DB-3-CP and TCP are carcinogenic through a mutagenic MOA, supported by experimental evidence of mutagenicity. The U.S. EPA (2004) report did not make a formal determination regarding a carcinogenic MOA for 1,2-DBE; however, available evidence suggested potential mutagenicity and/or DNA damage as potential MOAs. Available data for 1,2-DCP were considered inadequate for a formal MOA analysis by U.S. EPA (2020c); however, DNA damage has been proposed as a potential mechanism. The U.S. EPA (1993) report did not evaluate potential carcinogenic MOAs for 1,2-DCE, but experimental data indicate that the chemical is both DNA damaging and mutagenic (see Step 3). Taken together, all analogues except 1,2-DCP have sufficient evidence of mutagenicity (see Step 3) to indicate a potential common mutagenic MOA for halogenated alkanes. Specifically, experimental data show that 1,2-DBE, 1,2-DCE, 1,2-DB-3-CP, and TCP form DNA-reactive episulfonium ions via cyclization of GSH adducts during metabolism. By analogy, both 1,2-DCP and the target compound, 1-bromo-2-chloroethane, are expected to form episulfonium ions as well (see Table C-4). Data for 1,2-DCE indicate that although oxidative metabolites appear to influence CAs, the formation of the episulfonium ion is likely the primary mutagen (Gwinn et al., 2011). However, 1,2-DCP is not considered a potent mutagen, and experimental data do not support the potential for GSH-mediated mutagenicity (U.S. EPA, 2020c; Akiba et al., 2017; IARC, 2017).

Table C-5 Comparison of Available Oral Carcinogenicity Data for 1-Bromo-2-Chloroethane (CASRN 107-04-0) and Candidate Analogues

Type of Data | 1-Bromo-2-Chloroethane CASRN 107-04-0 | 1,2-Dibromoethane CASRN 106-93-4 | 1,2-Dichloroethane CASRN 107-06-2 | 1,2-Dichloropropane CASRN 78-87-5 | 1,2-Dibromo-3-Chloropropane CASRN 96-12-8 | 1,2,3-Trichloropropane CASRN 96-18-4
Structure | structure diagram | structure diagram | structure diagram | structure diagram | structure diagram | structure diagram
U.S. EPA WOE characterization | “Inadequate Information to Assess Carcinogenic Potential”; (see Table 6) | “Likely to Be Carcinogenic to Humans” | “Probable Human Carcinogen” | “Likely to Be Carcinogenic to Humans” | “Likely to Be Carcinogenic to Humans” | “Likely to Be Carcinogenic to Humans”
OSF (mg/kg-d)^−1^ | NDr | 2 (upper bound)^a^ | 9.1 × 10^−2^ | 3.7 × 10^−2^ (provisional) | 8 × 10^−1^ (provisional) | 3 × 10^1^ (upper bound)^b^
Data set(s) used for slope factor derivation | NA | Forestomach tumors, hemangiosarcomas, and thyroid follicular cell adenomas or carcinomas in male rats | Hemangiosarcoma in male rats | Hepatocellular adenoma or carcinoma in male mice | Renal adenoma or carcinoma in male rat | Alimentary system, liver, Harderian gland, and uterine tumors in female mice
Other tumors observed in animal oral bioassays | ND | Rat: forestomach, thyroid, or liver tumors and hemangiosarcomas (females); Mouse: forestomach and lung tumors, esophageal papilloma (female) | Rat: forestomach and mammary gland tumors; Mouse: lung, liver, and uterus tumors; malignant lymphoma | Rat: mammary gland tumors (marginal increase in females); Mouse: liver tumors (female), thyroid tumors (female) | Rat: mammary gland and kidney tumors (female), liver tumors (male), forestomach and stomach tumors (both); Mouse: forestomach and stomach tumors | Rat: alimentary system and Zymbal gland tumors (both); pancreatic, preputial gland, and kidney tumors (males); clitoral and mammary gland tumors (females); Mouse: alimentary system, Harderian gland, and liver tumors (males)
Study doses (mg/kg-d) | NA | TWA: 0, 38, 41; HED^b^: 0, 11, 22 | TWA: 0, 47, 95; HED: 0, 4.46, 8.23 | TWA: 0, 89.3, 179; HED: 0, 12.5, 25.1 | TWA: 0, 0.24, 0.80, 2.39; HED: not reported per dose (HED conversion done after OSF calculation) | 0, 6, 20, 60; HED: not reported per dose (HED conversion done after BMD modeling)
Route (method) | NA | Gavage in corn oil (5 d/wk) | Gavage in corn oil (5 d/wk) | Gavage in corn oil (5 d/wk) | Diet | Gavage
Duration | NA | 49 wk | 78 wk, followed by untreated observation period up to 32 wk | 103 wk | 104 wk | 2 yr; all high-dose females sacrificed after 73 wk
POD type | NA | BMDL_10_ (HED) | BMDL (linearized multistage with time-to-death analysis, extra risk) | BMDL_10_ (HED) | BMDL_10_ (HED) | BMDL_10_ (HED)
Source | NA | NTP (2016c); U.S. EPA (2004) | NTP (2016d); U.S. EPA (2020c); U.S. EPA (2010) | U.S. EPA (2020c) | U.S. EPA (2006) | U.S. EPA (2009)

a An upper bound on cancer risk was estimated by adding the central tendency risk estimates for the three tumor types and calculating an upper confidence limit on the sum, using an estimate of the variance pooled across the three slope factors. The resulting (upper bound) slope factor was adjusted for daily exposure by multiplying by 5 days/7 days and for lifetime exposure by dividing by (49 weeks/104 weeks).

b HED values were reported in the modeling section of U.S. EPA (2004) and appear to correlate with initial doses of 40 and 80 mg/kg-day, not TWA doses that reflect lowered dose in the high-dose group.

BMD = benchmark dose; BMDL = benchmark dose lower confidence limit; BMDL_10_ = 10% benchmark dose lower confidence limit; HED = human equivalent dose; NA = not applicable; ND = no data; NDr = not determined; OSF = oral slope factor; POD = point of departure; TWA = time-weighted average; WOE = weight of evidence.

Table C-6 Comparison of Available Inhalation Carcinogenicity Toxicity Data for 1-Bromo-2-Chloroethane (CASRN 107-04-0) and Candidate Analogues

Type of Data | 1-Bromo-2-Chloroethane CASRN 107-04-0 | 1,2-Dibromoethane CASRN 106-93-4 | 1,2-Dichloroethane CASRN 107-06-2 | 1,2-Dichloropropane CASRN 78-87-5 | 1,2-Dibromo-3-Chloropropane CASRN 96-12-8 | 1,2,3-Trichloropropane CASRN 96-18-4
Structure | structure diagram | structure diagram | structure diagram | structure diagram | structure diagram | structure diagram
WOE characterization | “Inadequate Information to Assess Carcinogenic Potential”; (see Table 6) | “Likely to Be Carcinogenic to Humans” | “Probable Human Carcinogen” | “Likely to Be Carcinogenic to Humans” | “Likely to Be Carcinogenic to Humans” | “Likely to Be Carcinogenic to Humans”
IUR (μg/m^3^)^−1^ | NDr | 6 × 10^−4^ (upper bound)^a^ | 2.6 × 10−5^b^; 1.0 × 10^−6^ (95% upper bound)^c^ | 3.7 × 10^−6^ (provisional) | 6 × 10^0^ (provisional) | NDr
Data set(s) used for slope factor derivation | NA | Nasal tumors (male and female rats, female mice), hemangiosarcomas (male and female rats, female mice), mesothelioma (male rats), lung tumors (female rats and mice), mammary tumors (female rats and mice), fibrosarcoma (female mice) | Hemangiosarcoma (oral study)^a^ | Nasal cavity tumors in male rats | Nasal cavity tumors in male rats | NA
Human carcinogenicity data | ND | Available occupational data inadequate to evaluate relationship between 1,2-DBE and cancer | Available occupational data inadequate to evaluate relationship between 1,2-DCE and cancer | Elevated risk of cholangiocarcinoma in print shop workers from several cohorts exposed to 1,2-DCP (and other chlorinated solvents) | Available occupational data inadequate to evaluate relationship between 1,2-DB-3-CP and cancer; no associations between gastric cancer or leukemia and 1,2-DB-3-CP in drinking water (case-control) | ND
Other tumors observed in animal inhalation bioassays | ND | Rat: splenic hemangiosarcoma, adrenal tumors, subcutaneous mesenchymal tumor | Inhalation study published since derivation of IUR:; Rat: mammary gland tumors, peritoneal mesothelioma, subcutaneous fibroma; Mouse: lung, liver, and mammary gland tumors (females) | Rats: nasal cavity tumors (female); Mice: Harderian gland tumors (male), lung tumors (female), hemangiocarcinoma (male) | Rats: nasal cavity, pharynx, adrenal gland, and mammary gland tumors (females), tongue tumors (both), mesothelioma (males); Mice: nasal and lung tumor (both) | ND
Study concentrations | NA | Reported (ppm): 0, 10, 40; HEC_ER_ (ppm): 0, 1.8, 7.1 (rat, mouse); HEC_ET_ (ppm): 0, 0.36, 1.42 (male rat, female mouse); 0, 0.25, 0.99 (female rat); HEC_PU_ (ppm) 0, 3.1, 12.3 (female rat); 0, 5.8, 22.7 (female mouse); HEC_TB_ (ppm) 0, 4.86, 19.2 (female mouse) | TWA (mg/kg-d): 0, 47, 95; HED (mg/kg-d): 0, 4.46, 8.23 | Analytical (ppm): 0, 80.2, 200.5, 500.2; HEC_ET_ (mg/m^3^): 0, 16.2, 40.54, 101.1 | Reported (ppm): 0, 0.6, 3; HEC_ET_ (mg/m^3^): 0, 0.23, 1.13 | NA
Route (method) | NA | Inhalation (6 h/d; 5 d/wk) | Gavage in corn oil (5 d/wk)^b^ | Inhalation (6 h/d; 5 d/wk) | Inhalation (6 h/d; 5 d/wk) | NA
Duration | NA | 79−104 wk | 78 wk, plus untreated observation period up to 32 wk | 104 wk | Control:; 105−107 wk; 0.6 ppm: 103 wk plus 1-wk observation; 3 ppm: 84 wk plus 0−1-wk observation | NA
POD type | NA | BMCL_10_ (HEC) | BMDL (linearized multistage with time-to-death analysis, extra risk) | BMCL_10_ (HEC) | BMCL_10_ (HEC) | NA
Source | NA | NTP (2016c); U.S. EPA (2004) | NTP (2016d); U.S. EPA (2010); U.S. EPA (1993) | IARC (2017); U.S. EPA (2020c) | NTP (2016b); U.S. EPA (2006); IARC (1995) | NTP (2016e); U.S. EPA (2009)

a An upper bound on cancer risk was estimated by using the multistage model with Poly-3 adjusted incidence data central tendency estimate for tumors at six sites in two species.

b Available inhalation data in 1987 was inadequate to derive an IUR (no induction of tumors); therefore, data from oral studies used to derive IUR in 1987 (the same major urinary metabolites and concentration from both oral and inhalation exposure) (Reitz et al., 1982). The IUR was calculated from oral data, assuming 100% absorption and metabolism at the low dose. See findings from oral study in Table C-5.

c Inferred unit risk from negative inhalation study (Maltoni et al., 1980).

1,2-DB-3-CP = 1,2-dibromo-3-chloropropane; 1,2-DBE = 1,2-dibromoethane; 1,2-DCE = 1,2-dichloroethane; 1,2-DCP = 1,2-dichloropropane; BMCL_10_ = 10% benchmark concentration lower confidence limit; BMDL = benchmark dose lower confidence limit; ER = extrarespiratory; ET = extrathoracic; HEC = human equivalent concentration; HED = human equivalent dose; IUR = inhalation unit risk; NA = not applicable; ND = no data; NDr = not determined; POD = point of departure; PU = pulmonary; TB = tracheobronchial; TWA = time-weighted average; WOE = weight of evidence.

## STEP 6 STRUCTURAL ALERTS AND STRUCTURE-ACTIVITY RELATIONSHIP PREDICTIONS FOR 1-BROMO-2-CHLOROETHANE AND ANALOGUES

Structural alerts (SAs) and predictions for genotoxicity and carcinogenicity were identified using computational tools as described in Appendix B. The model results for 1-bromo-2-chloroethane and its analogue compounds are shown in Table C-7. Concerns for carcinogenicity and/or mutagenicity of 1-bromo-2-chloroethane and its analogues were indicated by several models within each predictive tool (see Table C-7). Table C-8 provides a list of the specific SAs that underlie the findings of a concern for carcinogenicity or mutagenicity in Table C-7.

OECD QSAR Toolbox models showed a concern for in vitro and in vivo mutagenicity for 1-bromo-2-chloroethane and all analogues based on structural alerts, a concern for CAs for 1-bromo-2-chloroethane, and concerns for all analogues based on protein binding alerts (see Table C-7). OECD QSAR Toolbox models also showed a concern for mutagenicity, CAs, and MN induction for 1-bromo-2-chloroethane, 1,2-DBE, 1,2-DCE, and 1,2-DCP; no results were reported for 1,2-DB-3-CP or TCP. The ToxRead and VEGA models also indicated a concern for mutagenicity for 1-bromo-2-chloroethane and all analogues.

OECD QSAR Toolbox models showed a concern for carcinogenicity for 1-bromo-2-chloroethane and all analogues based on structural alerts (see Table C-8). The level of carcinogenicity concern in OncoLogic was “moderate” for 1-bromo-2-chloroethane and 1,2-DCE based on SAR analysis only (haloalkanes and haloalkenes structural alert) and 1,2-dichloropropane based on experimental data and SAR analysis (haloalkanes and haloalkenes structural alert). The level of carcinogenicity concern in OncoLogic was “high-moderate” for 1,2-DBE, 1,2-DB-3-CP, and TCP based on experimental data and SAR analysis (haloalkanes and haloalkenes structural alert). Two carcinogenicity models in VEGA showed concern for carcinogenicity for 1-bromo-2-chloroethane (ISS and IFRMN/ANTARES). The CAESAR and IRFMN/ISSCAN-CGX models did not have reliable data for 1-bromo-2-chloroethane. For analogues, all four carcinogenicity models in VEGA showed concern for carcinogenicity for 1,2-DBE, 1,2-DCE, 1,2-DB-3-CP, and TCP. For 1,2-DCP, the ISS and IRFMN/ISSCAN-CGX models in VEGA showed concern for carcinogenicity, but the CAESAR and IRFMN/ANTARES models showed no concern for carcinogenicity. The ToxAlerts tool showed concern for nongenotoxic carcinogenicity for 1-bromo-2-chloroethane and all analogues based on structural alerts (aliphatic halogens). In contrast, the Toxtree tool indicated that there was no concern for nongenotoxic carcinogenicity for 1-bromo-2-chloroethane or any of its analogues.

The ToxAlerts and Toxtree tools showed a concern for genotoxic carcinogenicity for 1-bromo-2-chloroethane and all analogues based on various structural alerts (see Table C-8).

Table C-7 Heat Map Illustrating the Structural Alert and SAR Prediction Results for 1-Bromo-2-Chloroethane (CASRN 107-04-0) and Analogues

Tool | Model^a^ | 1-Bromo-2-chloroethane | 1,2-Dibromoethane | 1,2-Dichloroethane | 1,2-Dichloropropane | 1,2-Dibromo-3-chloropropane | 1,2,3-Trichloropropane
Mutagenicity/genotoxicity alerts
OECD QSAR Toolbox | DNA alerts for Ames by OASIS
OECD QSAR Toolbox | DNA alerts for CA and MNT by OASIS
OECD QSAR Toolbox | In vitro mutagenicity (Ames test) alerts by ISS
OECD QSAR Toolbox | In vivo mutagenicity (micronucleus) alerts by ISS
OECD QSAR Toolbox | Protein binding alerts for CA by OASIS
ToxRead | ToxRead (mutagenicity)
VEGA | Mutagenicity (Ames test) CONSENSUS model—assessment
VEGA | Mutagenicity (Ames test) model (CAESAR)—assessment
VEGA | Mutagenicity (Ames test) model (SARpy/IRFMN)—assessment
VEGA | Mutagenicity (Ames test) model (ISS)—assessment
VEGA | Mutagenicity (Ames test) model (k-NN/read-across)—assessment
Carcinogenicity alerts
OECD QSAR Toolbox | Carcinogenicity (genotoxicity and nongenotoxicity) alerts by ISS
OncoLogic | OncoLogic (prediction of the carcinogenic potential of the chemical)
VEGA | Carcinogenicity model (CAESAR)—assessment
VEGA | Carcinogenicity model (ISS)—assessment
VEGA | Carcinogenicity model (IRFMN/ANTARES)—assessment
VEGA | Carcinogenicity model (IRFMN/ISSCAN-CGX)—assessment
ToxAlerts | Aliphatic halogens (for nongenotoxic carcinogenicity)
Toxtree | Nongenotoxic carcinogenicity
Combined alerts
ToxAlerts | Aliphatic halide (general) (for genotoxic carcinogenicity, mutagenicity)
ToxAlerts | Aliphatic halide (specific) (for genotoxic carcinogenicity, mutagenicity)
ToxAlerts | Aliphatic halogens (for genotoxic carcinogenicity, mutagenicity)
ToxAlerts | Aromatic and aliphatic substituted primary alkyl halides (for genotoxic carcinogenicity, mutagenicity)
ToxAlerts | Structural alert for genotoxic carcinogenicity
Toxtree | Model results outside the applicability domain for carcinogenicity/mutagenicity.
| Model results or alerts indicating no concern for carcinogenicity/mutagenicity.
| Model results outside the applicability domain for carcinogenicity/mutagenicity.
| Model results or alerts indicating concern for carcinogenicity/mutagenicity.

a All tools and models described in Appendix B were used. Models with results or alerts are presented in the heat map (models without results were omitted).

ANTARES = Alternative Non-Testing Methods Assessed for REACH Substances; CA = chromosomal aberration; CAESAR = Computer-Assisted Evaluation of industrial chemical Substances According to Regulations; CONSENSUS = consensus assessment based on multiple models (CAESAR, SARpy, ISS, and k-NN); DNA = deoxyribonucleic acid; IRFMN = Istituto di Ricerche Farmacologiche Mario Negri; ISS = Istituto Superiore di Sanità; ISSCAN-CGX = Istituto Superiore di Sanità Chemical Carcinogen; k-NN = k-nearest neighbor; MNT = micronucleus test; OECD = Organisation for Economic Co-operation and Development; QSAR = quantitative structure-activity relationship; REACH = Registration, Evaluation, Authorisation and Restriction of Chemicals; SAR = structure-activity relationship; VEGA = Virtual models for property Evaluation of chemicals within a Global Architecture.

Table C-8 Structural Alerts for 1-Bromo-2-Chloroethane (CASRN 107-04-0) and Analogues

SA | Tool | Compounds
Haloalkanes and haloalkenes | OncoLogic | 1-Bromo-2-chloroethane^a^,1,2-DBE^b^, 1,2-DCE,^a^ 1,2-DCP^c^, 1,2-DB-3-CP^b^, TCP^b^
Aliphatic halogens | ToxAlerts | 1-Bromo-2-chloroethane, 1,2-DBE, 1,2-DCE, 1,2-DCP, 1,2-DB-3-CP, TCP
Aliphatic halogens | Toxtree | 1-Bromo-2-chloroethane, 1,2-DBE, 1,2-DCE, 1,2-DCP, 1,2-DB-3-CP, TCP
Aliphatic halogens | OECD QSAR Toolbox | 1-Bromo-2-chloroethane, 1,2-DBE, 1,2-DCE, 1,2-DCP, 1,2-DB-3-CP, TCP
Aliphatic halide | ToxAlerts | 1-Bromo-2-chloroethane, 1,2-DBE, 1,2-DCE, 1,2-DCP, 1,2-DB-3-CP, TCP
Aromatic and aliphatic substituted primary alkyl halides | ToxAlerts | 1-Bromo-2-chloroethane, 1,2-DBE, 1,2-DCE, 1,2-DCP, 1,2-DB-3-CP, TCP
Vicinal dihaloalkanes | OECD QSAR Toolbox | 1-Bromo-2-chloroethane, 1,2-DBE, 1,2-DCE, 1,2-DCP
Halogenated vicinal hydrocarbons | OECD QSAR Toolbox | 1-Bromo-2-chloroethane, 1,2-DBE, 1,2-DCE, 1,2-DCP, 1,2-DB-3-CP, TCP

a Identified as moderate alert based on SAR analysis only.

b Identified as high-moderate alert based on experimental data and SAR analysis.

c Identified as moderate alert based on experimental data and SAR analysis.

1,2-DB-3-CP = 1,2-dibromo-3-chloropropane; 1,2-DBE = 1,2-dibromoethane; 1,2-DCE = 1,2-dichloroethane; 1,2-DCP = 1,2-dichloropropane; OECD = Organisation for Economic Co-operation and Development; QSAR = quantitative structure-activity relationship; SA = structural alert; SAR = structure-activity relationship; TCP = 1,2,3-trichloropropane.

## STEP 7 EVIDENCE INTEGRATION FOR SCREENING EVALUATION OF 1-BROMO-2-CHLOROETHANE CARCINOGENICITY

Table C-9 presents the data for multiple lines of evidence pertinent to the screening evaluation of the carcinogenic potential of 1-bromo-2-chloroethane.

Table C-9 Integration of Evidence for 1-Bromo-2-Chloroethane (CASRN 107-04-0) and Analogues

Evidence Streams | 1-Bromo-2-Chloroethane CASRN 107-04-0 | 1,2-Dibromoethane CASRN 106-93-4 | 1,2-Dichloroethane CASRN 107-06-2 | 1,2-Dichloropropane CASRN 78-87-5 | 1,2-Dibromo-3-Chloropropane CASRN 96-12-8 | 1,2,3-Trichloropropane CASRN 96-18-4
Structure | structure diagram | structure diagram | structure diagram | structure diagram | structure diagram | structure diagram
Analogue selection and evaluation; (see Steps 1 and 2) | Target compound Contains: (1) two labile halogen substituents; (2) halogens attached to adjacent, primary carbon atoms; and (3) no more than one halogen per carbon atom | Contains: (1) two labile halogen substituents; (2) halogens attached to adjacent, primary carbon atoms; and (3) no more than one halogen per carbon atom | Contains: (1) two labile halogen substituents; (2) halogens attached to adjacent, primary carbon atoms; and (3) no more than one halogen per carbon atom | Contains: (1) two labile halogen substituents; (2) halogens attached to adjacent, primary carbon atoms; and (3) no more than one halogen per carbon atom | Contains: (1) three labile halogen substituents; (2) halogens attached to adjacent, primary carbon atoms; and (3) no more than one halogen per carbon atom | Contains: (1) three labile halogen substituents; (2) halogens attached to adjacent, primary carbon atoms; and (3) no more than one halogen per carbon atom
Experimental genotoxicity data; (see Step 3) | Mutagenic; Clastogenic; DNA damaging; Forms DNA adducts | Mutagenic; Clastogenic; DNA damaging; Forms DNA adducts; Induces cell transformation | Mutagenic; Clastogenic; DNA damaging; Forms DNA adducts | Not a potent mutagen; Clastogenic; DNA damaging | Mutagenic; Clastogenic; DNA damaging; Forms DNA adducts; Induces cell transformation | Mutagenic; Clastogenic; DNA damaging; Forms DNA adducts; Induces cell transformation
ADME evaluation; (see Step 4) | Oxidation (based on analogy to other dihaloalkanes) and GSH conjugation (demonstrated); Expected to form episulfonium ion | Common metabolic pathways with other haloalkanes (oxidation and GSH conjugation); Forms episulfonium ion | Common metabolic pathways with other haloalkanes (oxidation and GSH conjugation); Forms episulfonium ion | Common metabolic pathways with other haloalkanes (oxidation and GSH conjugation); Expected to form episulfonium ion | Common metabolic pathways with other haloalkanes (oxidation and GSH conjugation); Forms episulfonium ion | Common metabolic pathways with other haloalkanes (oxidation and GSH conjugation); Forms episulfonium ion
Cancer data and MOA^a^; (see Step 5) | No data | Multisite carcinogen in rats and mice following oral or inhalation exposure; Proposed MOA: Mutagenicity and/or DNA damage | Multisite carcinogen in rats and mice following oral or inhalation exposure; Potential MOA: Mutagenicity and/or DNA damage | Liver tumors (mice) and marginal increase in mammary gland tumors (rats) following oral exposure; nasal tumors (rats) and lung and Harderian gland tumors (mice) following inhalation exposure; Proposed MOA: DNA damage | Multisite carcinogen in rats and mice following oral exposure; primarily respiratory tract cancer (nasal, pharynx, lung) following inhalation exposure; MOA: mutagenicity | Multisite carcinogen in rats and mice following oral exposure; no inhalation data; MOA: mutagenicity
Common structural alerts and SAR predictions; (see Step 6) | ALERTS; - Haloalkanes and haloalkenes; - Aliphatic halogens; - Aliphatic halide; - Vicinal dihaloalkanes; - Halogenated vicinal hydrocarbons; SAR PREDICTIONS:; Concerns for mutagenicity and carcinogenicity in most models; no concern for nongenotoxic carcinogenicity in Toxtree | ALERTS; - Haloalkanes and haloalkenes; - Aliphatic halogens; - Aliphatic halide; - Vicinal dihaloalkanes; - Halogenated vicinal hydrocarbons; SAR PREDICTIONS:; Concerns for mutagenicity and carcinogenicity in most models; no concern for nongenotoxic carcinogenicity in Toxtree | ALERTS; - Haloalkanes and haloalkenes; - Aliphatic halogens; - Aliphatic halide; - Vicinal dihaloalkanes; - Halogenated vicinal hydrocarbons; SAR PREDICTIONS:; Concerns for mutagenicity and carcinogenicity in most models; no concern for nongenotoxic carcinogenicity in Toxtree | ALERTS; - Haloalkanes and haloalkenes; - Aliphatic halogens; - Aliphatic halide; - Vicinal dihaloalkanes; - Halogenated vicinal hydrocarbons; SAR PREDICTIONS:; Concerns for mutagenicity and carcinogenicity in most models; no concern for carcinogenicity in two of four VEGA models and no concern for nongenotoxic carcinogenicity in Toxtree | ALERTS; - Haloalkanes and haloalkenes; - Aliphatic halogens; - Aliphatic halide; - Halogenated vicinal hydrocarbons; SAR PREDICTIONS:; Concerns for mutagenicity and carcinogenicity in most models; no concern for nongenotoxic carcinogenicity in Toxtree | ALERTS; - Haloalkanes and haloalkenes; - Aliphatic halogens; - Aliphatic halide; - Halogenated vicinal hydrocarbons; SAR PREDICTIONS:; Concerns for mutagenicity and carcinogenicity in most models; no concern for nongenotoxic carcinogenicity in Toxtree

a For MOA descriptions, “MOA” was used if the U.S. EPA did a formal MOA evaluation and made a conclusion regarding cancer MOA(s); “proposed MOA” was used if the U.S. EPA did not do formal MOA evaluation, but proposed possible MOAs; and “potential MOA” was used if the U.S. EPA did not discuss potential MOAs but available experimental data suggest an MOA.

ADME = absorption, distribution, metabolism, excretion; DNA = deoxyribonucleic acid; GSH = glutathione; MOA = mode of action; SAR = structure-activity relationship; VEGA = Virtual models for property Evaluation of chemicals within a Global Architecture.

## STEP 8 QUALITATIVE LEVEL OF CONCERN FOR 1-BROMO-2-CHLOROETHANE POTENTIAL CARCINOGENICITY

Table C-10 identifies the qualitative level of concern for potential carcinogenicity of 1-bromo-2-chloroethane based on the multiple lines of evidence described above. Due to lack of information supporting carcinogenic portal-of-entry effects, the qualitative level of concern for this chemical is considered to be applicable to all routes of exposure.

Table C-10 Qualitative Level of Concern for Carcinogenicity of 1-Bromo-2-Chloroethane (CASRN 107-04-0)

Level of Concern | Designation | Comments
Concern for potential carcinogenicity | Selected | All analogues of 1-bromo-2-chloroethane have carcinogenic potential based on tumors observed in rodent studies. The U.S. EPA identified a mutagenic MOA for 1,2-DB-3-CP and TCP, and all analogues except 1,2-DCP are mutagenic (evidence is limited for 1,2-DCP). DNA damage is also a potential MOA suggested for 1,2-DBE and 1,2-DCP, and experimental evidence indicates that all analogues are DNA damaging and all except 1,2-DCP form DNA adducts (no data for 1,2-DCP). Common metabolic pathways exist between 1-bromo-2-chloroethane and the analogue compounds. 1-Bromo-2-chloroethane and its analogues have similar structural alerts (e.g., haloalkanes and haloalkenes, aliphatic halogens, aliphatic halide, halogenated vicinal hydrocarbons) and similar SAR predictions showing concern for carcinogenicity and/ or genotoxicity.
Inadequate information for assigning qualitative level of concern | Not selected | NA

1,2-DB-3-CP = 1,2-dibromo-3-chloropropane; 1,2-DBE = 1,2-dibromoethane; 1,2-DCP = 1,2-dichloropropane; DNA = deoxyribonucleic acid; MOA = mode of action; NA = not applicable; SAR = structure-activity relationship; TCP = 1,2,3-trichloropropane.