# APPENDIX A SCREENING NONCANCER PROVISIONAL VALUES

Due to the lack of evidence described in the main Provisional Peer-Reviewed Toxicity Value (PPRTV) document, it is inappropriate to derive provisional toxicity values for 1-bromo-2-chloroethane. However, some information is available for this chemical, which although insufficient to support derivation of a provisional toxicity value under current guidelines, may be of limited use to risk assessors. In such cases, the Center for Public Health and Environmental Assessment (CPHEA) summarizes available information in an appendix and develops a “screening value.” Appendices receive the same level of internal and external scientific peer review as the provisional reference values to ensure their appropriateness within the limitations detailed in the document. Users of screening toxicity values in an appendix to a PPRTV assessment should understand that there could be more uncertainty associated with deriving an appendix screening toxicity value than for a value presented in the body of the assessment. Questions or concerns about the appropriate use of screening values should be directed to the CPHEA.

## APPLICATION OF AN ALTERNATIVE ANALOGUE APPROACH

The analogue approach allows for the use of data from related compounds to calculate screening values when data for the compound of interest are limited or unavailable. Details regarding searches and methods for analogue analysis are presented in Wang et al. (2012). Three types of potential analogues (structural, metabolic, and toxicity-like) are identified to facilitate the final analogue chemical selection. The analogue approach may or may not be route-specific or applicable to multiple routes of exposure. All information was considered together as part of the final weight-of-evidence (WOE) approach to select the most suitable analogue both toxicologically and chemically.

### Structural Analogues

An initial analogue search focused on the identification of structurally similar chemicals with toxicity values from the Integrated Risk Information System (IRIS), PPRTVs, Agency for Toxic Substances and Disease Registry (ATSDR), or California Environmental Protection Agency (CalEPA) databases to leverage the body of well-characterized chemical-class information. As described in Wang et al. (2012), structural similarity for analogues is evaluated using the National Library of Medicine’s (NLM’s) ChemIDplus database (ChemIDplus, 2021) and the Organisation for Economic Co-operation and Development (OECD) Toolbox. Both structural similarity approaches were used to calculate structural similarity using the Tanimoto method. Three structural analogues to 1-bromo-2-chloroethane that have oral and/or inhalation toxicity values were identified: 1,2-dibromoethane (U.S. EPA, 2004), 1,2-dichloroethane (U.S. EPA, 2010), and 1,2-dibromo-3-chloropropane (U.S. EPA, 2006, 2003). Table A-1 summarizes the analogues’ physicochemical properties and similarity scores. ChemIDplus similarity scores were available only for 1,2-dibromoethane (92%) and 1,2-dichloroethane (68%). OECD Quantitative Structure-Activity Relationship (QSAR) pairwise toolbox similarity scores were similar for all three candidate analogues (24−33%) and the target chemical. The target compound and all candidate analogues are expected to be bioavailable by oral and inhalation routes (based on water solubility and K_ow_ values). A range of vapor pressure values (0.580−78.9 mm Hg at 25°C) is identified for 1-bromo-2-chloroethane and relevant analogue chemicals, suggesting that these compounds may exhibit differences in volatility. All of the candidate analogues are considered appropriate structural analogues based on the approach described in Wang et al. (2012).

Table A-1 Physicochemical Properties of 1-Bromo-2-Chloroethane (CASRN 107-04-0) and Candidate Analogues^a^

Property | 1-Bromo-2-Chloroethane | 1,2-Dibromoethane | 1,2-Dichloroethane | 1,2-Dibromo-3-Chloropropane (2R and 2S Isomers)
Structure | [image] | structure diagram | structure diagram | structure diagram
CASRN | 107-04-0 | 106-93-4 | 107-06-2 | 96-12-8
Molecular weight | 143 | 188 | 99 | 236
OECD QSAR Toolbox similarity score (%)^b^ | 100 | 33 | 33 | 24
ChemIDplus similarity score (%)^c^ | 100 | 92 | 68 | NV
Melting point (°C) | −16.3 | 9.8 | −35.3 | 6.04
Boiling point (°C) | 107 | 132 | 83.2 | 196
Vapor pressure (mm Hg at 25°C) | 33.1 | 11.2 | 78.9 | 0.580
Henry’s law constant (atm-m^3^/mole at 25°C) | 9.09 × 10^−4^ | 6.50 × 10^−4^ | 1.18 × 10^−3^ | 2.93 × 10^−4^ (predicted)
Water solubility (mol/L) | 4.79 × 10^−2^ | 2.11 × 10^−2^ | 8.68 × 10^−2^ | 4.71 × 10^−3^
Octanol-water partition coefficient (log K_ow_) | 1.86 (predicted) | 1.96 | 1.48 | 2.96

a Data represent average values as reported on the U.S. EPA’s CompTox Chemicals Dashboard unless otherwise specified (https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID4024775#properties). Data accessed June 2021.

b OECD (2018).

c ChemIDplus advanced similarity scores (ChemIDplus, 2021).

NV = not available; OECD =Organisation for Economic Co-operation and Development; QSAR = quantitative structure-activity relationship.

### Metabolic Analogues

Table A-2 summarizes available toxicokinetic data for 1-bromo-2-chloroethane and the structurally similar compounds identified as candidate analogues.

#### Absorption, Distribution, and Excretion

No data are available to describe the absorption, distribution, or excretion of 1-bromo-2-chloroethane. Oral absorption is rapid and extensive for all three candidate analogue compounds (U.S. EPA, 2004; ATSDR, 2001; Gingell et al., 1987). Absorption is also rapid and extensive following inhalation exposure to 1,2-dibromoethane and 1,2-dichloroethane (U.S. EPA, 2004; ATSDR, 2001). There are no data available on the rate or extent of absorption following inhalation exposure to 1,2-dibromo-3-chloropropane. Widespread distribution to multiple organs and excretion primarily in the urine has been demonstrated for all three candidate analogue compounds (U.S. EPA, 2004; ATSDR, 2001; Gingell et al., 1987).

Table A-2 Comparison of Available ADME Data for 1-Bromo-2-Chloroethane (CASRN 107-04-0) and Candidate Analogues

Parameter | 1-Bromo-2-Chloroethane | 1,2-Dibromoethane | 1,2-Dichloroethane | 1,2-Dibromo-3-Chloropropane (2R and 2S isomers)
Structure | structure diagram | structure diagram | structure diagram | structure diagram
CASRN | 107-04-0 | 106-93-4 | 107-06-2 | 96-12-8
Absorption
Rate and extent of oral absorption | ND | Rat:; rapid and extensive (C_max_ within 30 min; >80% of dose absorbed) | Rat:; rapid and extensive (C_max_ within 15 min; >80% of dose absorbed) | Rat:; rapid and extensive (C_max_ within 5−40 min; >80% of dose absorbed)
Rate and extent of inhalation absorption | ND | Rat:; rapid and extensive (C_max_ within 20 min; 40 to <60% of dose absorbed) | Rat:; rapid and extensive (C_max_ within 1−3 h; >80% of dose absorbed) | ND
Human blood-gas partition coefficient^a^ | 29.2 | ND | 19.5 | ND
Rat blood-gas partition coefficient^a^ | 52.7 | 119 | 30.4 | ND
Distribution
Extent of distribution | ND | Rat and mouse:; wide distribution to multiple organs; covalent binding to tissues (kidney, stomach, liver, and testis after oral exposure; nasal mucosa, liver, lung, kidney, and small intestine after i.p. injection) | Rat:; wide distribution to multiple organs; transplacental distribution was demonstrated | Rat:; wide distribution to multiple organs; V_d_ = 4.98 L/kg (oral)
Metabolism—oxidation by CYP450
Primary reactive metabolites | By analogy to 1,2-dibromoethane and 1,2-dichloroethane:; (1) 2-bromo-acetaldehyde;; (2) 2-chloro-acetaldehyde; structure diagram; X = Br, Cl; By analogy to 1,2-dibromoethane and 1,2-dichloroethane:; (3) HBr, HCl | Demonstrated:; (1) 2-bromo-acetaldehyde; structure diagram; Demonstrated:; (2) HBr | Demonstrated:; (1) 2-chloro-acetaldehyde; structure diagram; Demonstrated:; (2) HCl | Demonstrated:; (1) 2-bromoacrolein; structure diagram; (2) 2-chloro-3-(bromomethyl) oxirane; structure diagram; (3) 1-bromo-3-chloroacetone; structure diagram; Demonstrated:; (4) HBr, HCl
Potential role in toxicity | By analogy to 1,2-dibromoethane and 1,2-dichloroethane:; (1) Forms DNA adducts; (2) Lipid peroxidation; (3) Protein binding | Demonstrated:; (1) Forms DNA adducts; (2) Lipid peroxidation; (3) Protein binding | Demonstrated:; (1) Forms DNA adducts; (2) Lipid peroxidation; (3) Protein binding | Demonstrated:; (1) 2-bromoacrolein and 2-chloro-3-(bromomethyl) oxirane are direct-acting mutagens in Salmonella; (2) 2-bromoacrolein forms DNA adducts
Metabolism—GSH conjugation^b^
Primary reactive metabolites | Inferred from CEG as primary GSH conjugate:; (1) HBr released during GSH conjugation (HCl released in minor amounts); By analogy to 1,2-dichloroethane:; (2) Reactive episulfonium ion formed following cyclization of GSH adduct; structure diagram | Inferred from BEG as GSH conjugate:; (1) HBr released during GSH conjugation; Demonstrated:; (2) Reactive episulfonium ion formed following cyclization of GSH adduct; structure diagram | Inferred from CEG as GSH conjugate:; (1) HCl released during GSH conjugation; Demonstrated:; (2) Reactive episulfonium ion formed following cyclization of GSH adduct; structure diagram | Inferred from CBPG as primary GSH conjugate:; (1) HBr released during GSH conjugation (HCl released in minor amounts); Demonstrated:; (2) Reactive episulfonium ion formed following cyclization of GSH adduct; structure diagram
Potential role in toxicity | By analogy to all potential analogues:; (1) Forms DNA adducts; By analogy to 1,2-dibromoethane and 1,2-dibromo-3-chloropropane:; (2) Causes DNA damage in cells including spermatocytes; Demonstrated:; (3) Mutagenicity among genotoxicity assays mediated by GSH activity | Demonstrated:; (1) Forms DNA adducts,; (2) Causes DNA damage in hepatocytes and spermatocytes (unscheduled DNA synthesis) | Demonstrated:; (1) Forms DNA adducts,; (2) Binds to protein and DNA in kidney and liver | Demonstrated:; (1) Forms DNA adducts,; (2) Causes DNA damage in multiple tissues including kidneys and testes (unscheduled DNA synthesis),; (3) DNA strand breaks in spermatocytes,; (4) DNA damage is correlated with tissue injury at higher doses
Excretion
Half-life in blood (h) | ND | ND | Rat, oral:; <1 | Rat, oral:; 2.64
Route of excretion | ND | Rat, oral:; 60 to <80% urine; <20% feces; <20% exhaled air (form not indicated) | Rat, oral:; 60 to <80% urine; <20% feces; 20 to <40% excreted unchanged in exhaled air; Rat, inhalation:; >80% urine; <20% feces; <20% as CO_2_ in exhaled air | Rat, oral:; 40 to <60% urine; <20% feces; 20 to <40% exhaled air (<1% unmetabolized; 20% as CO_2_)
References | Guengerich (1994); Dekant and Vamvakas (1993); Jean and Reed (1992); Gargas et al. (1989); Marchand and Reed (1989); Guengerich et al. (1987); van Bladeren et al. (1981); Wheeler et al. (2001); Shimada et al. (1996) | U.S. EPA (2004); Gargas et al. (1989); Guengerich et al. (1987); NTP (2021) | ATSDR (2001); Gargas et al. (1989); Guengerich et al. (1987) | Guengerich (1994); van Beerendonk et al. (1994); Dekant and Vamvakas (1993); Humphreys et al. (1991); Pearson et al. (1990); Dohn et al. (1988); Omichinski et al. (1988a); Omichinski et al. (1988b); Gingell et al. (1987); Guengerich et al. (1987)

a Values represent means in the case of multiple studies.

b Metabolism information was categorized as: (1) experimentally demonstrated, (2) inferred from other experimental data for the same compound, or (3) by analogy to experimental data for a different compound.

ADME = absorption, distribution, metabolism, and excretion; BEG = S-(2-bromoethyl)glutathione; Br = bromine; CBPG = S-(3-chloro-2-bromopropyl) glutathione; CEG = S-(2-chloroethyl)glutathione; C_max_ = maximum concentration; Cl = chlorine; CO_2_ = carbon dioxide; CYP450 = cytochrome P450; DNA = deoxyribonucleic acid; GSH = glutathione; HBr = hydrogen bromide; HCl = hydrogen chloride; i.p. = intraperitoneal; ND = no data; V_d_ = volume of distribution.

#### Metabolism

Each of the candidate analogue compounds is metabolized by a cytochrome P450 (CYP450) oxidation pathway and a direct glutathione (GSH) conjugation pathway. Contributions from both pathways are presumed by analogy for the target compound as well; however, experimental data for 1-bromo-2-chloroethane (the target compound) are available only for the GSH conjugation pathway. Formation of a reactive episulfonium ion occurs, or is expected to occur, for all compounds. Although metabolic pathways are similar among the target chemical and potential analogues, available data indicate that the rate of GSH conjugation and the specific products of oxidative metabolism differ between compounds.

Studies suggest that GSH conjugation leads to the formation of reactive intermediates for the target compound and potential analogues. As discussed in the “Absorption, Distribution, Metabolism, and Excretion” (ADME) section in the main document, 1-bromo-2-chloroethane was metabolized to S-(2-chloroethyl)glutathione (CEG) in bile-duct-cannulated rats (Marchand and Reed, 1989). GSH conjugation to CEG is also suggested by formation of S-(2-hydroxyethyl)glutathione (HEG), a hydrolysis product of CEG, in isolated rat hepatocytes (Jean and Reed, 1992). Metabolic studies with 1,2-dichloroethane (which also forms CEG by GSH conjugation) report that once formed, CEG cyclizes to form an electrophilic episulfonium ion in vivo, which subsequently binds to deoxyribonucleic acid (DNA) [reviewed by Guengerich (1994); Dekant and Vamvakas (1993)]. Similar electrophilic metabolites (i.e., episulfonium ions) were also produced following GSH conjugation to 1,2-dibromoethane to form S-(2-bromoethyl)glutathione (BEG) and to 1,2-dibromo-3-chloropropane to form S-(3-chloro-2-bromopropyl) glutathione (CBPG), also resulting in DNA and protein binding and subsequent damage to DNA (NTP, 2021; U.S. EPA, 2004; ATSDR, 2001; Guengerich, 1994; van Beerendonk et al., 1994; Dekant and Vamvakas, 1993; Pearson et al., 1990; Dohn et al., 1988; Omichinski et al., 1988b; Omichinski et al., 1988a; Guengerich et al., 1987). The rate of GSH conjugation is anticipated to be faster for the brominated compounds compared with 1,2-dichloroethane because of the increased relative reactivity of the bromine versus the chlorine leaving group. This is demonstrated by the initial GSH conjugation products identified for both 1-bromo-2-chloroethane and the proposed analogue 1,2-dibromo-3-chloropropane. When both chlorine and bromine substituents are present, GSH conjugation occurs preferentially at the brominated site (yielding CEG and CBPG, respectively) (Dekant and Vamvakas, 1993; Jean and Reed, 1992; Humphreys et al., 1991; Marchand and Reed, 1989). The concomitant release of hydrogen bromide (HBr) (with minor release of hydrogen chloride [HCl]) is inferred (i.e., not experimentally demonstrated) by the preference for GSH conjugation at the brominated site. Halogen reactivity (i.e., bromine vs. chlorine) is expected to have less influence on the rate of the cyclization reaction that occurs subsequent to GSH conjugation, because the reacting centers are held in close proximity to each other, resulting in rapid formation of the episulfonium ion from the GSH adduct in all cases.

Oxidative metabolites differ among the candidate analogue compounds. CYP450-mediated oxidation of 1,2-dibromoethane and 1,2-dichloroethane results in the production of haloacetaldehyde metabolites that can cause lipid peroxidation and bind to cellular proteins and DNA (NTP, 2021; U.S. EPA, 2004; ATSDR, 2001). HBr and HCl are released during the formation of the haloacetaldehyde metabolite (NTP, 1991; van Bladeren et al., 1981). Although not experimentally demonstrated, this pathway is expected for the target compound as well, based on analogy to the candidate analogue compounds. Oxidative metabolism of 1,2-dibromo-3-chloroethane produces three primary metabolites (2-bromoacrolein, 2-chloro-3-[bromomethyl] oxirane, 1-bromo-3-chloroacetone) (Pearson et al., 1990; Dohn et al., 1988; Omichinski et al., 1988b), none of which can be produced by oxidation of the target compound due to structural constraints. Both HBr and HCl are released during the formation of 2-bromoacrolein, while only HBr is released during the formation of 2-chloro-3-(bromomethyl) oxirane and 1-bromo-3-chloroacetone (Omichinski et al., 1988b). 2-Bromoacrolein and 2-chloro-3-(bromomethyl) oxirane are electrophilic and have been shown to be clastogenic and direct-acting mutagens in Salmonella (van Beerendonk et al., 1994; Pearson et al., 1990). 2-Bromoacrolein has also been demonstrated to bind to DNA, and the resulting adducts have been characterized (van Beerendonk et al., 1994).

Because of the preference for relative reactivity of the bromine versus the chlorine leaving group during GSH conjugation, 1,2-dibromoethane and 1,2-dibromo-3-chloropropane are favored as metabolic analogues over 1,2-dichloroethane. Assuming that both CYP450 oxidation and GSH conjugation are equally relevant to the toxicity of the target compound, 1,2-dibromoethane is the most appropriate choice as a metabolic analogue. If the GSH conjugation pathway predominates in its relevance to toxicity, 1,2-dibromo-3-chloropropane may be a more appropriate metabolic analogue.

### Toxicity-Like Analogues—Oral

Table A-3 summarizes available oral toxicity values for 1-bromo-2-chloroethane and the compounds identified as potential structural analogues.

Table A-3 Comparison of Available Oral Toxicity Data for 1-Bromo-2-Chloroethane (CASRN 107-04-0) and Candidate Analogues

Parameter | 1-Bromo-2-Chloroethane | 1,2-Dibromoethane | 1,2-Dichloroethane | 1,2-Dibromo-3-Chloropropane
Structure | structure diagram | structure diagram | structure diagram | structure diagram
CASRN | 107-04-0 | 106-93-4 | 107-06-2 | 96-12-8
Repeated-dose toxicity—subchronic
POD (mg/kg-d) | NA | NA | 58 | 0.7
POD type | NA | NA | LOAEL | NOAEL
Subchronic UF_C_ | NA | NA | 3,000 (UF_A_, UF_D_, UF_H_, UF_L_) | 300 (UF_A_, UF_D_, UF_H_)
Subchronic p-RfD (mg/kg-d) | NA | NA | 2 × 10^−2^ | 2 × 10^−3^
Critical effects^a^ | NA | NA | Increased absolute kidney weight in female rats | Male reproductive toxicity (reduced germ cell number)
Species | NA | NA | Rat | Rabbit
Duration | NA | NA | 13 wk | 10 wk
Route (method) | NA | NA | Drinking water | Drinking water
Source | NA | NA | U.S. EPA (2010) | U.S. EPA (2006)
Repeated-dose toxicity—chronic
POD (mg/kg-d) | NA | 27 | 58 | 0.7
POD type | NA | LOAEL (ADJ) | LOAEL | NOAEL
Chronic UF_C_ | NA | 3,000 (UF_A_, UF_D_, UF_H_, UF_L_) | 10,000 (UF_A_, UF_D_, UF_H_, UF_L_, UF_S_) | 3,000 (UF_A_, UF_D_, UF_H_, UF_S_)
Chronic RfD/p-RfD (mg/kg-d) | NA | 9 × 10^−3^ | 6 × 10^−3^ (screening) | 2 × 10^−4^
Critical effects^a^ | NA | Liver peliosis, testicular atrophy, and adrenal cortical degeneration | Increased absolute kidney weight in female rats | Testicular toxicity (reduced germ cell number)
Species | NA | Rat (M and F) | Rat | Rabbit
Duration | NA | 49 wk (M);; 61 wk (F) | 13 wk | 10 wk
Route (method) | NA | Gavage in corn oil (5 d/wk) | Drinking water | Drinking water
Source | NA | U.S. EPA (2004) | U.S. EPA (2010) | U.S. EPA (2006)
Acute oral lethality data
Rat oral LD_50_ (mg/kg) | 64 | 55−420 | 670−967 | 170
Toxicity at rat LD_50_ | NR | NR | NR | NR
Source | U.S. EPA (2020b); U.S. EPA (1985) | U.S. EPA (2020b); U.S. EPA (2004) | U.S. EPA (2020a) | U.S. EPA (2020b)

a Exposure-response arrays were prepared to illustrate the dose-response relationship for testicular, kidney, and liver effects across the candidate analogue compounds (Figures A-1, A-2, and A-3, respectively).

ADJ = duration adjusted; F = female(s); LD_50_ = median lethal dose; LOAEL = lowest-observed-adverse-effect level; M = male(s); NA = not applicable; NOAEL = no-observed-adverse-effect level; NR = not reported; POD = point of departure; p-RfD = provisional reference dose; RfD = oral reference dose; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

No repeated-dose oral toxicity data are available for 1-bromo-2-chloroethane. Acute toxicity data are limited to a reported median lethal dose (LD_50_) of 64 mg/kg-day in rats; no further information was provided [Frear (1969) as cited in NLM (2016)].

Oral toxicity values are available for 1,2-dibromoethane, 1,2-dichloroethane, and 1,2-dibromo-3-chloropropane (see Table A-3), and the data supporting these values are extensive [as cited in U.S. EPA (2010, 2006, 2004)]. The target organs of toxicity for these potential analogues include the testis, kidney, and liver (see exposure-response arrays in Figures A-1, A-2, and A-3). After review of the available data for candidate analogues, testicular effects are identified as the most sensitive toxicity target after exposure to 1,2-dibromo-3-chloropropane and 1,2-dibromoethane.

Testicular effects occurred at the lowest oral doses for 1,2-dibromoethane and 1,2-dibromo-3-chloropropane and are identified as being among the critical effects for derivation of provisional reference dose (p-RfD) values for both compounds (see Table A-3, Figure A-1). In support of this endpoint, epidemiological studies of 1,2-dibromo-3-chloropropane-exposed production workers, farmers and pesticide applicators have demonstrated impaired testicular function (decreased spermatogenesis and sperm count and altered sperm morphology) in exposed humans. The testicular toxicity of 1,2-dibromo-3-chloropropane is known to be mediated exclusively by the GSH conjugation pathway because the inhibition of this pathway completely abrogated the observed testicular effects (Omichinski et al., 1988a; Søderlund et al., 1988). Reactive episulfonium metabolites are well known to bind to DNA and promote increased rates of DNA damage. Within the context of the 1,2-dibromo-3-chloropropane database, reactive episulfonium metabolites were observed to produce increased amounts of testicular DNA damage, promote testicular necrosis and atrophy at higher doses (Søderlund et al., 1988), and in turn, impair spermatogenesis and prolong oligospermia (Meistrich et al., 2003). This same sequence of events is likely to occur for 1,2-dibromoethane and 1-bromo-2-chloroethane, which are anticipated to undergo GSH conjugation at similar rates to 1,2-dibromo-3-chloropropane due to the presence of bromine leaving groups in all three compounds. This reaction leads to formation of the reactive episulfonium metabolites that are implicated in testicular toxicity. The absence of testicular toxicity following exposure to 1,2-dichloroethane (see Figure A-1) may be attributable to reduced episulfonium formation secondary to the expected slower rate of GSH conjugation resulting from lower reactivity of the chlorine leaving group relative to bromine (see “Metabolic Analogues” section for more details).

In the absence of repeated-exposure oral toxicity data for 1-bromo-2-chloroethane, there is no information with which to clearly identify or rule out candidate analogues based on toxicity comparisons. However, based on the expected formation of the episulfonium ion following metabolism of 1-bromo-2-chloroethane, the mechanism of action for the critical testicular effects following exposure to 1,2-dibromo-3-chloropropane (and by analogy 1,2-dibromoethane) is plausible for 1-bromo-2-chloroethane as well.

Figure A-1 Testicular Effects Following Oral Exposure to 1,2-Dichloroethane (1,2-DCE), 1,2-Dibromoethane (1,2-DBE), or 1,2-Dibromo-3-Chloropropane (1,2-DB-3-CP) [reviewed by U.S. EPA (2010, 2006, 2004)]

This is the beginning of the long description for Figure A dash 1. Figure A dash 1 is titled Testicular Effects Following Oral Exposure to 1 2 Dichloroethane (or 1 2 D C E), 1 2 Dibromoethane (or 1 2 D B E), or 1 2 Dibromo 3 Chloropropane (or 1 2 D B 3 C P) as Reviewed by U S E P A 2010, 2006, and 2004. The figure depicts doses above the L O A E L, the L O A E L, the N O A E L, and below the N O A E L for each compound in the various studies reviewed. Administered doses in milligrams per kilogram per day are along the y-axis. The x-axis lists studies broken down by compound, duration of the study, and the effects observed. This is the end of the long description for Figure A dash 1.

Figure A-2 Kidney Effects Following Oral Exposure to 1,2-Dichloroethane (1,2-DCE), 1,2-Dibromoethane (1,2-DBE), or 1,2-Dibromo-3-Chloropropane (1,2-DB-3-CP) [reviewed by U.S. EPA (2010, 2006, 2004)]

This is the beginning of the long description for Figure A dash 2. Figure A dash 2 is titled Kidney Effects Following Oral Exposure to 1 2 D C E, 1 2 D B E, or 1 2 D B 3 C P as Reviewed by U S E P A 2010, 2006, and 2004. The figure depicts doses above the L O A E L, the L O A E L, the N O A E L, and below the N O A E L for each compound in the various studies reviewed. Administered doses in milligrams per kilogram per day are along the y-axis. The x-axis lists studies broken down by compound, duration of the study, and the effects observed. This is the end of the long description for Figure A dash 2.

Figure A-3 Liver Effects Following Oral Exposure to 1,2-Dichloroethane (1,2-DCE), 1,2-Dibromoethane (1,2-DBE), or 1,2-Dibromo-3-Chloropropane (1,2-DB-3-CP) [reviewed by U.S. EPA (2010, 2006, 2004)]

This is the beginning of the long description for Figure A dash 3. Figure A dash 3 is titled Liver Effects Following Oral Exposure to 1 2 D C E, 1 2 D B E, or 1 2 D B 3 C P as Reviewed by U S E P A 2010, 2006, and 2004. The figure depicts doses above the L O A E L, the L O A E L, the N O A E L, and below the N O A E L for each compound in the various studies reviewed. Administered doses in milligrams per kilogram per day are along the y-axis. The x-axis lists studies broken down by compound, duration of the study, and the effects observed. This is the end of the long description for Figure A dash 3.

### Toxicity-Like Analogues—Inhalation

Table A-4 summarizes available inhalation toxicity values for the compounds identified as potential structural analogues for 1-bromo-2-chloroethane.

Table A-4 Comparison of Available Inhalation Toxicity Data for 1-Bromo-2-Chloroethane (CASRN 107-04-0) and Candidate Analogues

Parameter | 1-Bromo-2-Chloroethane | 1,2-Dibromoethane | 1,2-Dichloroethane | 1,2-Dibromo-3-Chloropropane
Structure | structure diagram | structure diagram | structure diagram | structure diagram
CASRN | 107-04-0 | 106-93-4 | 107-06-2 | 96-12-8
Repeated-dose toxicity—subchronic
POD (mg/m^3^) | NA | NA | 22 | 0.17
POD type | NA | NA | LOAEL (ADJ) | NOAEL (HEC)
Subchronic UF_C_ | NA | NA | 300 (UF_D_, UF_H_, UF_L_) | 100 (UF_A_, UF_D_, UF_H_)
Subchronic p-RfC (mg/m^3^) | NA | NA | 7 × 10^−2^ | 2 × 10^−3^
Critical effects^a^ | NA | NA | Neurobehavioral impairment (impaired visual-motor reactions) | Testicular effects (decreased absolute testis-weight, atrophy, loss of spermatogenic elements in seminiferous tubules)
Species | NA | NA | Human | Rabbit
Duration | NA | NA | No information on length of employment or duration of exposure was reported; treated as subchronic in the PPRTV assessment | 14 wk
Route (method) | NA | NA | Inhalation (occupational) | Inhalation (whole body; 6 h/d, 5 d/wk)
Source | NA | U.S. EPA (2004) | U.S. EPA (2010) | U.S. EPA (2006); U.S. EPA (2003)
Repeated-dose toxicity—chronic
POD (mg/m^3^) | NA | 2.8 | 22 | 0.17
POD type | NA | BMCL_10_ (HEC) | LOAEL (ADJ) | NOAEL (HEC)
Chronic UF_C_ | NA | 300 (UF_A_, UF_D_, UF_H_) | 3,000 (UF_D_, UF_H_, UF_L_, UF_S_) | 1,000 (UF_A_, UF_D_, UF_H_, UF_S_)
Chronic RfC/p-RfC (mg/m^3^) | NA | 9 × 10^−3^ | 7 × 10^−3^ | 2 × 10^−4^
Critical effects^a^ | NA | Suppurative inflammation of nasal cavity in female mice | Neurobehavioral impairment (impaired visual-motor reactions) | Testicular effects (decreased absolute testis weight, atrophy, loss of spermatogenic elements in seminiferous tubules)
Species | NA | Mouse | Human | Rabbit
Duration | NA | 78 wk (M); 90−106 wk (F) | No information on length of employment or duration of exposure was reported; treated as subchronic in the PPRTV assessment | 14 wk
Route (method) | NA | Inhalation (whole body; 6 h/d, 5 d/wk) | Inhalation (occupational) | Inhalation (whole body; 6 h/d, 5 d/wk)
Source | NA | U.S. EPA (2004) | U.S. EPA (2010) | U.S. EPA (2006); U.S. EPA (2003)
Acute inhalation lethality data
LC_50_ (mg/m^3^) | 15,000−25,000 (30-min; unspecified species) | ~1,500 (9 h; rat) | 7,758 (4 h; rat) | ND
Source | U.S. EPA (1985) | U.S. EPA (2004) | U.S. EPA (2020a) | U.S. EPA (2020b)

a Exposure-response arrays were prepared to illustrate the dose-response relationship for testicular, kidney, liver, and respiratory tract effects in experimental animal inhalation studies across the candidate analogue compounds (see Figures A-4, A-5, A-6, and A-7, respectively).

ADJ = duration adjusted; BMCL_10_ = 10% benchmark concentration lower confidence limit; F = female(s); HEC = human equivalent concentration; LC_50_ = median lethal concentration; LOAEL = lowest-observed-adverse-effect level; M = male(s); NA = not applicable; ND = no data; NOAEL = no-observed-adverse-effect level; POD = point of departure; PPRTV = provisional peer-reviewed toxicity value; p-RfC = provisional reference concentration; RfC = inhalation reference concentration; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

No repeated-exposure inhalation toxicity data are available for 1-bromo-2-chloroethane. Acute inhalation toxicity data are limited to a single study by Valade et al. (1957) as cited in U.S. EPA (1985), which reports a 30-minute median lethal concentration (LC_50_) value of 15,000−25,000 mg/m^3^ in unspecified laboratory animals. This study also indicates that acute inhalation of “several alkyl halides” caused ataxia in dogs, rats, and guinea pigs; however, it is unclear whether these halides included 1-bromo-2-chloroethane.

Inhalation toxicity values are available for 1,2-dichloroethane, 1,2-dibromoethane, and 1,2-dibromo-3-chloropropane (see Table A-4), and the data supporting these values are extensive [reviewed by U.S. EPA (2010, 2006, 2004, 2003)]. Target organs and systems of toxicity for potential analogues include the testis, kidney, liver, nervous system, and respiratory tract (see exposure-response arrays in Figures A-4, A-5, A-6, and A-7). Although neurobehavioral impairment was observed following occupational exposure to 1,2-dichloroethane (impaired visual-motor reactions in two of three tests), an exposure-response array was not prepared for this endpoint because no additional neurobehavioral studies were identified for any candidate analogue in humans or laboratory animals. No information is available regarding the potential mode of action (MOA) for the observed neurobehavioral effects in humans or animals. Upon review of the available inhalation toxicity data, testicular and respiratory effects are identified as the most sensitive toxicity endpoints among the candidate analogues.

Epidemiology studies of 1,2-dibromo-3-chloropropane-exposed production workers, farmers, and pesticide applicators have demonstrated impaired testicular function (decreased spermatogenesis and sperm count and altered sperm morphology) in exposed humans. Testicular effects were identified as critical effects for assessment of 1,2-dibromo-3-chloropropane inhalation toxicity in animal studies. A comparison of rat, mouse, and rabbit data indicates that the rabbit is the most sensitive of these species for testicular effects (by both inhalation and oral exposure). Oral data indicate that testicular toxicity of 1,2-dibromo-3-chloropropane is mediated exclusively by the GSH conjugation pathway (Omichinski et al., 1988a; Søderlund et al., 1988). This is likely the case also for 1,2-dibromoethane and 1-bromo-2-chloroethane, which are anticipated to undergo GSH conjugation at similar rates because of the expected similar reactivity of the bromine leaving groups. This reaction leads to the formation of the reactive episulfonium ion metabolites that are implicated in testicular toxicity (see “Toxicity-Like Analogues—Oral” section above for more details).

Inhalation exposure to the candidate analogues 1,2-dibromoethane and 1,2-dibromo-3-chloropropane in rats and mice produced respiratory tract lesions, with nasal effects occurring at lower concentrations than lesions observed in the bronchial, bronchiolar, and alveolar regions. Respiratory lesions may result, at least in part, from the production of HBr (from both CYP450 oxidation and GSH conjugation) in the respiratory tract. Nasal irritation has been observed in volunteers and laboratory animals exposed to HBr gas (NRC, 2014). By analogy, HBr formation and respiratory lesions may also be expected to occur for the 1-bromo-2-chloroethane target compound. In contrast, 1,2-dichloroethane does not produce nasal or other respiratory tract lesions following inhalation exposure. This may be partially explained by the slower release of chlorine relative to bromine during GSH conjugation, resulting in a reduced rate of generation of HCl in the respiratory tract of exposed animals (relative to HBr from the other compounds). The lack of effect by 1,2-dichloroethane supports the hypothesized role of HBr in the observed respiratory effects.

Other cytotoxic mechanisms may contribute to the nasal toxicity of 1,2-dibromoethane; these include lipid peroxidation and/or protein binding induced by anticipated or experimentally determined metabolites (e.g., 2-bromoacetaldehyde) (U.S. EPA, 2004). By analogy, formation of 2-bromoacetaldehyde and subsequent nasal and/or respiratory lesions may also be expected to occur for the 1-bromo-2-chloroethane target compound.

In the absence of repeated-exposure inhalation toxicity data for 1-bromo-2-chloroethane, there is no information with which to clearly identify or rule out candidate analogues based on toxicity comparisons. However, based on the expected formation of the episulfonium ion following metabolism of 1-bromo-2-chloroethane, the mechanism of action for testicular toxicity following exposure to 1,2-dibromo-3-chloropropane (and by analogy 1,2-dibromoethane) is plausible for 1-bromo-2-chloroethane. Based on the expected formation of HBr and 2-bromoacetaldehyde following metabolism of 1-bromo-2-chloroethane, respiratory toxicity is also plausible for 1-bromo-2-chloroethane.

Figure A-4 Testicular Effects Following Inhalation Exposure to 1,2-Dichloroethane (1,2-DCE), 1,2-Dibromoethane (1,2-DBE), or 1,2-Dibromo-3-Chloropropane (1,2-DB-3-CP) [reviewed by U.S. EPA (2010, 2006, 2004, 2003)]

Figure A-5 Kidney Effects Following Inhalation Exposure to 1,2-Dichloroethane (1,2-DCE), 1,2-Dibromoethane (1,2-DBE), or 1,2-Dibromo-3-Chloropropane (1,2-DB-3-CP) [reviewed by U.S. EPA (2010, 2006, 2004, 2003)]

Figure A-6 Liver Effects Following Inhalation Exposure to 1,2-Dichloroethane (1,2-DCE), 1,2-Dibromoethane (1,2-DBE), or 1,2-Dibromo-3-Chloropropane (1,2-DB-3-CP) [reviewed by U.S. EPA (2010, 2006, 2004, 2003)]

Figure A-7 Respiratory Tract Effects Following Inhalation Exposure to 1,2-Dichloroethane (1,2-DCE), 1,2-Dibromoethane (1,2-DBE), or 1,2-Dibromo-3-Chloropropane (1,2-DB-3-CP) [reviewed by U.S. EPA (2010, 2006, 2004, 2003)]

This is the beginning of the long description for Figure A dash 7. Figure A dash 7 is titled Respiratory Tract Effects Following Inhalation Exposure to 1 2 D C E, 1 2 D B E, or 1 2 D B 3 C P as Reviewed by U S E P A 2010, 2006, 2004, and 2003. The figure depicts concentrations above the L O A E L, the L O A E L, the N O A E L, and below the N O A E L for each compound in the various studies reviewed. Human equivalent concentrations in milligrams per cubic meter are along the y-axis. The x-axis lists studies broken down by compound, duration of the study, and the effects observed. This is the end of the long description for Figure A dash 7.

### Weight-of-Evidence Approach

To select the best analogue chemical based on all of the information described within the three analogue similarity tiers prescribed in Wang et al. (2012), the following considerations are used in a weight-of-evidence (WOE) approach: (1) lines of evidence from U.S. EPA assessments are preferred; (2) biological and toxicokinetic data are preferred over the structural similarity scores; (3) lines of evidence that indicate pertinence to humans are preferred; (4) chronic studies are preferred over subchronic studies when selecting an analogue for a chronic value; (5) chemicals with more sensitive toxicity values may be favored; and (6) if there are no clear indications as to the best analogue chemical based on the other considerations, then the candidate analogue with the highest structural similarity scores may be preferred.

#### Oral

The WOE approach used to select the analogue compound for 1-bromo-2-chloroethane is based on mechanistic and metabolism considerations related to the most sensitive critical effect (i.e., testicular toxicity). Unlike 1,2-dibromoethane and 1,2-dibromo-3-chloropropane, 1,2-dichloroethane is not a testicular toxicant. This may be explained by differences in the rate and extent of GSH adduct formation due in part to differences in the chemical reactivity of the brominated versus the chlorinated compounds. 1,2-Dibromoethane will react more rapidly with GSH than 1,2-dichloroethane because bromide is a better chemical leaving group in comparison to the chloride. That is, the C-Br bond is more readily cleaved than is the C-Cl bond. The results of this difference are demonstrated by the metabolic products and GSH adducts formed by 1-bromo-2-chloroethane and 1,2-dibromo-3-chloropropane. In both cases, bromine is preferentially displaced when both C-Br and C-Cl bonds are available. The only GSH-conjugated product detected from 1-bromo-2-chloroethane metabolism was CEG, and episulfonium products of 1,2-dibromo-3-chloropropane contain chlorine, indicating that bromine was preferentially released during metabolism (Dekant and Vamvakas, 1993; Jean and Reed, 1992; Humphreys et al., 1991; Marchand and Reed, 1989). These data suggest that from the available identified potential analogue chemicals, chemicals with a bromine leaving group are expected to be more relevant as an analogue for 1-bromo-2-chloroethane. The presence of this group is expected to significantly influence the rate of GSH conjugation (and ultimately the rate of toxic moiety production) over analogues containing chlorine leaving groups.

By analogy, 1-bromo-2-chloroethane can be expected to form the same episulfonium ion that is formed from 1,2-dibromoethane and 1,2-dichloroethane after GSH conjugation (see Table A-2). In the initial reaction, bromine will be preferentially displaced from 1-bromo-2-chloroethane. Although this compound and 1,2-dichloroethane are both expected to lead to the same initial adduct, 1-bromo-2-chloroethane is expected to react faster because of the presence of a bromide versus chloride leaving group, leading to a higher localized concentration of the proximal toxicant. Therefore, the rate of initial adduct formation is expected to be more similar to 1,2-dibromoethane and 1,2-dibromo-3-chloropropane than to 1,2-dichloroethane. Available data suggest that the cyclization of the GSH adducts for each respective analogue is rapid and immediate, and that this step (leading to the production of the toxic episulfonium ion moiety) is not likely to be the rate-limiting step in the metabolism of the parent chemicals.

Given the demonstrated significance of the presence of a bromide leaving group in metabolism and expected toxicity, 1-bromo-2-chloroethane, 1,2-dibromoethane, and 1,2-dibromo-3-chloropropane were determined to be more appropriate analogues compared with 1,2-dichloroethane. Ultimately, 1,2-dibromo-3-chloropropane is selected as the most appropriate analogue compound for both subchronic and chronic effects because the demonstrated testicular effect of this chemical on sperm is the most sensitive measure of toxicity among the favored brominated analogues.

#### Inhalation

The WOE approach used to select the analogue compound for 1-bromo-2-chloroethane is based on mechanistic considerations related to sensitive effects for the candidate brominated analogues following inhalation exposure (i.e., testicular toxicity and respiratory effects). The absence of testicular and respiratory tract effects for 1,2-dichloroethane may be explained, at least in part, by a decrease in the rate and extent of GSH conjugation (i.e., bromine is a better chemical leaving group than chlorine), leading to a lower localized concentration of proximal toxicants (i.e., episulfonium ion, HCl). 1-Bromo-2-chloroethane can be expected to form both the reactive episulfonium metabolite (responsible for testicular effects) and HBr (which may contribute to respiratory lesions) at a similar rate as 1,2-dibromoethane and 1,2-dibromo-3-chloropropane. Both 1,2-dibromoethane and 1,2-dibromo-3-chloropropane release HBr during GSH conjugation, and this is expected to occur for 1-bromo-2-chloroethane. As described above, the rate of GSH conjugation among brominated compounds, rapid cyclization of GSH conjugates to generate reactive episulfonium ions, and the release of HBr during GSH conjugation suggest that the brominated analogues are more appropriate surrogate chemicals for 1-bromo-2-chloroethane than 1,2-dichloroethane. However, these characteristics do not provide a means to sufficiently differentiate amongst the brominated analogues.

Ultimately, 1,2-dibromo-3-chloropropane is selected as the analogue compound for both subchronic and chronic inhalation exposure because the demonstrated effect of this chemical on sperm is among the most sensitive measures of toxicity among the favored brominated analogues, and the relevance of this endpoint to humans is supported by the observation of similar effects in exposed workers (U.S. EPA, 2006).

## NONCANCER ORAL TOXICITY VALUES

### Derivation of a Screening Subchronic Provisional Reference Dose

Based on the overall analogue approach presented in this PPRTV assessment, 1,2-dibromo-3-chloropropane is selected as the analogue for 1-bromo-2-chloroethane for deriving a screening subchronic p-RfD. The study used for the U.S. EPA subchronic p-RfD for 1,2-dibromo-3-chloropropane was a 10-week reproductive study in rabbits [Foote et al. (1986a, b) as cited in U.S. EPA (2006)] described as follows:

Groups of 6 male Dutch rabbits were exposed to drinking water that provided reported DBCP intakes of 0, 0.94, 1.88, 3.75, 7.5 or 15.0 mg/kg on 5 days/week (0, 0.7, 1.3, 2.7, 5.4 or 10.7 mg/kg-day) for 10 weeks (Foote et al., 1986a, 1986b). General health, body weight, semen quality, and libido were evaluated throughout the study. Assessments of fertility (mated with untreated females) and serum levels of reproductive hormones (follicle stimulation hormone, luteinizing hormone and testosterone) were performed during the last week of the study. Endpoints evaluated following sacrifice at the end of the study included organ weights (liver, kidneys, testes, epididymides, accessory sex glands), quantitative histology of testes and epididymides, and sperm morphology and forward motility and morphology. There were no statistically significant (p < 0.05) changes in any of the study endpoints at 0.7 mg/kg-day. Effects observed at higher doses included dose-related reductions in numbers of all germ cell types within Stage I seminiferous tubular cross sections (significantly reduced numbers of spermatogonia and preleptotene spermatocytes at >1.3 mg/kg-day, pachytene spermatocytes at >2.7 mg/kg-day, and round spermatids at >5.4 mg/kg-day) (Table 1 [in U.S. EPA 2006]). Other effects included dose-related significantly reduced numbers of leptotene primary spermatocytes per Sertoli cell at >2.7 mg/kg-day, and significantly reduced mean diameter of seminiferous tubules and increased percentage of sperm with abnormal tails at >5.4 mg/kg-day (Table 2 [in U.S. EPA 2006]). Testis weight and volume, and sperm production (number of seminiferous tubules with round or elongating spermatids), output (ejaculate volume times sperm concentration) and motility were reduced, and serum FSH level was increased, at 10.7 mg/kg-day (Table 3 [in U.S. EPA 2006].). Fertility was not affected at any dose level, as assessed by number of males producing young, number or percentage of live births, total number of young, average litter size, and gestation length. The results summarized above are based on comparisons of mean data from the treated and control groups. Regression analyses showed highly significant correlations between DBCP dosage and essentially all of the testicular responses. The findings of this study indicate that rabbits are more sensitive than rats to testicular effects of DBCP. This study identified a NOAEL of 0.7 mg/kg-day and LOAEL of 1.3 mg/kg-day for reproductive toxicity in male rabbits.

The critical effect in this study was testicular toxicity in male rabbits; the no-observed-adverse-effect level (NOAEL) of 0.7 mg/kg-day was used as the point of departure (POD) for 1,2-dibromo-3-chloropropane (U.S. EPA, 2006) and is adopted as the analogue POD for the current assessment of 1-bromo-2-chloroethane.

For the current assessment, the NOAEL of 0.7 mg/kg-day was converted to a human equivalent dose (HED) according to current (U.S. EPA, 2011c) guidance. In Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011c), the Agency endorses body-weight scaling to the 3/4 power (i.e., BW^3/4^) as a default to extrapolate toxicologically equivalent doses of orally administered agents from all laboratory animals to humans for the purpose of deriving an RfD from effects that are not portal-of-entry effects.

Following U.S. EPA (2011c) guidance, the POD for testicular effects in male rabbits is converted to an HED by applying a dosimetric adjustment factor (DAF) derived as follows:

DAF = ( BW_a_ 1 / 4 ÷ BW_h_ 1 / 4 )

where

- DAF = dosimetric adjustment factor
- BW_a_ = animal body weight
- BW_h_ = human body weight

Using a reference BW_a_ of 2.86 kg for rabbits and a reference BW_h_ of 70 kg for humans (U.S. EPA, 1988), the resulting DAF is 0.45. Applying this DAF to the NOAEL of 0.7 mg/kg-day yields a POD (HED) as follows:

POD ( HED ) = NOAEL ( mg/kg-day ) × DAF = 0.7 mg/kg-day × 0.45 = 0.3 mg/kg-day

The U.S. EPA (2006) subchronic p-RfD for 1,2-dibromo-3-chloropropane was derived using a composite uncertainty factor (UF_C_) of 300, reflecting 10-fold uncertainty factors for interspecies extrapolation and intraspecies variability and a 3-fold uncertainty factor for database uncertainties (UF_A_, UF_H_, and UF_D_, respectively). Wang et al. (2012) indicated that the uncertainty factors typically applied in deriving a toxicity value for the selected analogue are the same as those applied to the chemical of concern unless additional information is available. For 1-bromo-2-chloroethane, a UF_A_ of 3 is applied because cross-species dosimetric adjustment was performed, and a UF_D_ of 10 was used to reflect the lack of repeated-dose toxicity data; the UF_H_ remained the same as for 1,2-dibromo-3-chloropropane. Thus, the screening subchronic p-RfD for 1-bromo-2-chloroethane is derived using a UF_C_ of 300.

Screening Subchronic p-RfD = Analogue POD ( HED ) ÷ UF_C_ = 0.3 mg/kg-day ÷ 300 = 1 × 10^− 3^ mg/kg-day

Table A-5 summarizes the uncertainty factors for the screening subchronic p-RfD for 1-bromo-2-chloroethane.

Table A-5 Uncertainty Factors for the Screening Subchronic p-RfD for 1-Bromo-2-Chloroethane (CASRN 107-04-0)

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^) is applied to account for uncertainty in characterizing the toxicokinetic or toxicodynamic differences between rabbits and humans following 1-bromo-2-chloroethane exposure. The toxicokinetic uncertainty has been accounted for by calculating an HED through application of a DAF as outlined in the U.S. EPA’s Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011c). Dosimetric adjustment calculations were performed on the POD for the selected analogue, 1,2-dibromo-3-chloropropane.
UF_D_ | 10 | A UF_D_ of 10 is applied to reflect database limitations for 1,2-dibromo-3-chloropropane and the absence of repeated-dose toxicity data for 1-bromo-2-chloroethane.
UF_H_ | 10 | A UF_H_ of 10 is applied for interindividual variability to account for human-to-human variability in susceptibility in the absence of quantitative information to assess the toxicokinetics and toxicodynamics of 1-bromo-2-chloroethane in humans.
UF_L_ | 1 | A UF_L_ of 1 is applied for LOAEL-to-NOAEL extrapolation because the POD is a NOAEL.
UF_S_ | 1 | A UF_S_ of 1 is applied because a subchronic study was selected as the principal study for the subchronic assessment.
UF_C_ | 300 | Composite uncertainty factor = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_.

DAF = dosimetric adjustment factor; HED = human equivalent dose; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; POD = point of departure; p-RfD = provisional reference dose; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

### Derivation of a Screening Chronic Provisional Reference Dose

1,2-Dibromo-3-chloropropane is also selected as the analogue for 1-bromo-2-chloroethane for deriving a screening chronic p-RfD. The key study and calculation of the POD (HED) are described above for the subchronic p-RfD. The uncertainty factors used for the screening subchronic p-RfD (UF_A_ of 3, UF_H_ of 10, and UF_D_ of 10) are applied, and a UF_S_ of 10 is applied to account for extrapolation from a subchronic to a chronic duration (consistent with the UF_S_ applied during the derivation of the chronic p-RfD for 1,2-dibromo-3-chloropropane). Thus, the screening chronic p-RfD for 1-bromo-2-chloroethane is derived using a UF_C_ of 3,000.

Screening Chronic p-RfD = Analogue POD ( HED ) ÷ UF_C_ = 0.3 mg/kg-day ÷ 3,000 = 1 × 10^− 4^ mg/kg-day

Table A-6 summarizes the uncertainty factors for the screening chronic p-RfD for 1-bromo-2-chloroethane.

Table A-6 Uncertainty Factors for the Screening Chronic p-RfD for 1-Bromo-2-Chloroethane (CASRN 107-04-0)

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^) is applied to account for uncertainty in characterizing the toxicokinetic or toxicodynamic differences between rabbits and humans following 1-bromo-2-chloroethane exposure. The toxicokinetic uncertainty has been accounted for by calculating an HED through application of a DAF as outlined in the U.S. EPA’s Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011c). Dosimetric adjustment calculations were performed on the POD for the selected analogue, 1,2-dibromo-3-chloropropane.
UF_D_ | 10 | A UF_D_ of 10 is applied to reflect database limitations for 1,2-dibromo-3-chloropropane and the absence of repeated-dose toxicity data for 1-bromo-2-chloroethane.
UF_H_ | 10 | A UF_H_ of 10 is applied for interindividual variability to account for human-to-human variability in susceptibility in the absence of quantitative information to assess the toxicokinetics and toxicodynamics of 1-bromo-2-chloroethane in humans.
UF_L_ | 1 | A UF_L_ of 1 is applied for LOAEL-to-NOAEL extrapolation because the POD is a NOAEL.
UF_S_ | 10 | A UF_S_ of 10 is applied because a subchronic study was selected as the principal study for the chronic assessment.
UF_C_ | 3,000 | Composite uncertainty factor = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_.

DAF = dosimetric adjustment factor; HED = human equivalent dose; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; POD = point of departure; p-RfD = provisional reference dose; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

## NONCANCER INHALATION TOXICITY VALUES

### Derivation of a Screening Subchronic Provisional Reference Concentration

Based on the overall analogue approach presented in this PPRTV assessment, 1,2-dibromo-3-chloropropane is selected as the most appropriate analogue for 1-bromo-2-chloroethane for deriving a screening subchronic p-RfC. The study used for the subchronic p-RfC for 1,2-dibromo-3-chloropropane was a 14-week study in rabbits [Rao et al. (1982) as cited in U.S. EPA (2006)]. U.S. EPA (2006) described the study as follows:

In rabbits, reproductive toxicity was evaluated in groups of 10 New Zealand white males (age 6 months) that were exposed to 0, 0.1, 1 or 10 ppm (0, 0.94, 9.4 or 94 mg/m^3^) vapor for 6 hours/day, 5 days/week for 14 weeks, and observed for the following 32 weeks (0, 0.1 and 1 ppm groups) or 38 weeks (10 ppm group) (Rao et al., 1982). The 10 ppm rabbits were exposed for only 8 weeks due to high mortality (apparently from pneumonia). Body weight and hematological and clinical chemistry parameters were evaluated, but no exposure related changes were found. No gross lesions were found in the lungs or upper respiratory tract, but these tissues were not examined histologically. Semen was collected during the exposure and recovery periods to assess sperm motility, viability and counts. The average sperm count of the 10-ppm rabbits was significantly less than that of the controls after 7 weeks of exposure, and remained decreased for the duration of the exposure and observation periods. At 1 ppm (9.4 mg/m^3^), sperm counts were significantly reduced, compared with controls, from weeks 11 to 13 of exposure. At 0.1 ppm (0.94 mg/m^3^), sperm counts were sporadically lower than control values (significantly reduced at only one interim time point). The percentage of live sperm in the semen of the 10 ppm (94 mg/m^3^) rabbits was also significantly reduced compared to controls during weeks 8−26. Rabbits exposed to 1 ppm (9.4 mg/m^3^), but not those exposed to 0.1 ppm (0.94 mg/m^3^), exhibited significant decreases in the percentage of live sperm during weeks 6, 12 and 13. From the 8th week of exposure onward, the 10-ppm (94 mg/m^3^) rabbits had a marked decrease in the percentage of progressively motile sperm; no consistent statistically significant decreases in this endpoint were found at <1 ppm (9.4 mg/m^3^) (Table 4 [in U.S. EPA 2006]). Abnormal spermatozoa within the seminiferous tubules were counted in 3−4 rabbits per group; the percentage of abnormal sperm at 14 weeks was 5% in controls, 10% at 0.1 ppm (0.94 mg/m^3^), and 18% at 1 ppm (9.4 mg/m^3^).

To assess the effects of DBCP on fertility in the rabbits, exposed males were mated to unexposed females at study weeks 14 and 41 (Rao et al., 1982) (Tables 5, 6 [in U.S. EPA 2006]). There were no effects on the libido of the exposed male rabbits during week 14, based on percentages of males (78−100%) that copulated with unexposed females. Five of the 10 males exposed to 10 ppm were infertile (none of the females that they were mated with became pregnant). The mean number of implantations/litter in the 1 ppm (9.4 mg/m^3^) group was significantly less than that of the control group. During week 41 (27 weeks post-exposure), all rabbits exposed to 0.1 or 1 ppm (0.94 or 9.4 mg/m^3^) DBCP produced normal litters, and 2 of the 5 infertile males exposed to 10 ppm (94 mg/m^3^) recovered (sperm counts increased) and produced normal litters. Serum levels of follicle stimulating hormone (FSH) were significantly elevated at 14 weeks in the males exposed to 1 ppm (9.4 mg/m^3^) and at 46 weeks in the males exposed to 10 ppm (94 mg/m^3^), but serum levels of testosterone were unchanged (Table 7 [in U.S. EPA 2006]). The increases in serum FSH were consistent with the decreases in sperm count. Gross pathologic examinations showed small testes size in rabbits exposed to 1 or 10 ppm. Testes weight was significantly decreased to 50% of control values (week 14) in the group exposed to 1 ppm (9.4 mg/m^3^) and to 75% of control values (week 8) in the group exposed to 10 ppm. Histological examinations showed reproductive system effects that included atrophy of the testes, epididymides, and accessory sex glands, including the prostate. The testicular atrophy was severe, as characterized by nearly complete or complete loss of spermatogenic elements in nearly all seminiferous tubules. Following the recovery period, tubular regeneration was observed in the testes of some 10 ppm (94 mg/m^3^) rabbits (3/5 had regeneration such that 25% of the seminiferous tubules appeared normal). At 1 ppm, testicular recovery was reported to be nearly complete in some rabbits (incidences not given). The testes of the 0.1 ppm rabbits appeared normal. The lack of exposure-related adverse testicular and fertility effects at 0.1 ppm indicates that this study identified a NOAEL of 0.1 ppm (0.94 mg/m^3^) and LOAEL of 1 ppm (9.4 mg/m^3^) for reproductive effects in rabbits.

The critical effect in this study was testicular toxicity in male rabbits; the NOAEL of 0.94 mg/m^3^ was used as the POD for 1,2-dibromo-3-chloropropane. The U.S. EPA (2006) calculated a POD (human equivalent concentration [HEC]) according to U.S. EPA (1994) guidance for Category 3 gases by adjusting intermittent exposure levels to a continuous exposure basis (U.S. EPA, 2002) and multiplying the result by a ratio of the animal blood-gas partition coefficient (concentration ÷ concentration) for 1,2-dibromo-3-chloropropane to the human blood-gas partition coefficient (concentration ÷ concentration) for 1,2-dibromo-3-chloropropane. Because blood-air partition coefficients for 1,2-dibromo-3-chloropropane are unknown, a default value of 1 was assigned.

POD ( HEC ) = NOAEL ( mg/m^3^ ) × ( hours exposed/24 hours ) × ( days/week exposed/7 days ) × ( animal blood-gas partition coefficient ÷ human blood-gas partition coefficient ) = 0.94 mg/m^3^ × ( 6 / 24 ) × ( 5 / 7 ) × 1 = 0.17 mg/m^3^

The POD (HEC) of 0.17 mg/m^3^ derived for 1,2-dibromo-3-chloropropane by U.S. EPA (2006) is adopted as the analogue POD (HEC) for the current assessment of 1-bromo-2-chloroethane.

The U.S. EPA (2006) subchronic p-RfC for 1,2-dibromo-3-chloropropane was derived using a UF_C_ of 100 to account for uncertainties due to interspecies extrapolation (UF_A_ = 3), intraspecies variability (UF_H_ = 10), and database uncertainties (UF_D_ = 3) (U.S. EPA, 2006). Wang et al. (2012) indicated that the uncertainty factors typically applied in deriving a toxicity value for the chemical of concern are the same as those applied to the analogue unless additional information is available. Because no repeated-exposure inhalation toxicity data are available for 1-bromo-2-chloroethane, a UF_D_ of 10 is used; other UF values remain the same as for 1,2-dibromo-3-chloropropane. Thus, the screening subchronic p-RfC for 1-bromo-2-chloroethane is derived using a UF_C_ of 300, reflecting a UF_A_ of 3, a UF_H_ of 10, and a UF_D_ of 10.

Screening Subchronic p-RfC = Analogue POD ( HEC ) ÷ UF_C_ = 0.17 mg/m^3^ ÷ 300 = 6 × 10^− 4^ mg/m^3^

Table A-7 summarizes the uncertainty factors for the screening subchronic p-RfC for 1-bromo-2-chloroethane.

Table A-7 Uncertainty Factors for the Screening Subchronic p-RfC for 1-Bromo-2-Chloroethane (CASRN 107-04-0)

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^) is applied to account for uncertainty associated with extrapolating from animals to humans when cross-species dosimetric adjustment (HEC calculation) is performed. Dosimetric adjustment calculations were performed on the POD for the selected analogue, 1,2-dibromo-3-chloropropane.
UF_D_ | 10 | A UF_D_ of 10 is applied to reflect database limitations for 1,2-dibromo-3-chloropropane and the absence of repeated-exposure toxicity data for 1-bromo-2-chloroethane.
UF_H_ | 10 | A UF_H_ of 10 is applied for interindividual variability to account for human-to-human variability in susceptibility in the absence of quantitative information to assess the toxicokinetics and toxicodynamics of 1-bromo-2-chloroethane in humans.
UF_L_ | 1 | A UF_L_ of 1 is applied for LOAEL-to-NOAEL extrapolation because the POD is a NOAEL.
UF_S_ | 1 | A UF_S_ of 1 is applied because a subchronic study was selected as the principal study for the subchronic assessment.
UF_C_ | 300 | Composite uncertainty factor = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_.

HEC = human equivalent concentration; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; POD = point of departure; p-RfC = provisional reference concentration; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

### Derivation of a Screening Chronic Provisional Reference Concentration

1,2-Dibromo-3-chloropropane is also selected as the analogue for 1-bromo-2-chloroethane for deriving a screening chronic p-RfC. The key study and calculation of the POD (HEC) are described above for the subchronic p-RfC. The uncertainty factor values used for the screening subchronic p-RfC (UF_A_ of 3, UF_H_ of 10, and UF_D_ of 10) are applied, and a UF_S_ of 10 is applied to account for extrapolation from a subchronic to a chronic duration (consistent with the UF_S_ applied during the derivation of the chronic RfC for 1,2-dibromo-3-chloropropane) (U.S. EPA, 2003). Thus, the screening chronic p-RfC for 1-bromo-2-chloroethane is derived using a UF_C_ of 3,000.

Screening Chronic p-RfC = Analogue POD ( HEC ) ÷ UF_C_ = 0.17 mg/m 3 ÷ 3,000 = 6 × 10^− 5^ mg/m^3^

Table A-8 summarizes the uncertainty factors for the screening chronic p-RfC for 1-bromo-2-chloroethane.

Table A-8 Uncertainty Factors for the Screening Chronic p-RfC for 1-Bromo-2-Chloroethane (CASRN 107-04-0)

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^) is applied to account for uncertainty associated with extrapolating from animals to humans when cross-species dosimetric adjustment (HEC calculation) is performed. Dosimetric adjustment calculations were performed on the POD for the selected analogue, 1,2-dibromo-3-chloropropane.
UF_D_ | 10 | A UF_D_ of 10 is applied to reflect database limitations for 1,2-dibromo-3-chloropropane and the absence of repeated-exposure toxicity data for 1-bromo-2-chloroethane.
UF_H_ | 10 | A UF_H_ of 10 is applied for interindividual variability to account for human-to-human variability in susceptibility in the absence of quantitative information to assess the toxicokinetics and toxicodynamics of 1-bromo-2-chloroethane in humans.
UF_L_ | 1 | A UF_L_ of 1 is applied for LOAEL-to-NOAEL extrapolation because the POD is a NOAEL.
UF_S_ | 10 | A UF_S_ of 10 is applied because a subchronic study was selected as the principal study for the chronic assessment.
UF_C_ | 3,000 | Composite uncertainty factor = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_.

HEC = human equivalent concentration; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; POD = point of departure; p-RfC = provisional reference concentration; UF = uncertainty factor(s); UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.