# 3 DERIVATION OF PROVISIONAL VALUES

## 3.1 DERIVATION OF PROVISIONAL REFERENCE DOSES

No studies have been located regarding toxicity of BeP to humans by oral exposure. Animal studies of oral exposure to BeP are limited to an acute study with limited hepatic endpoints and a subchronic cardiovascular study in apoE-KO mice of inadequate design and scope to support derivation of a subchronic or chronic provisional reference dose (p-RfD). As a result of the limitations of the available oral toxicity data for BeP, subchronic and chronic p-RfDs were not derived directly. Instead, screening subchronic and chronic p-RfDs are derived in Appendix A using an alternative analogue approach. Based on the overall analogue approach presented in Appendix A, BaP was selected as the most appropriate analogue for BeP for deriving a screening subchronic and chronic p-RfD (see Table 5).

## 3.2 DERIVATION OF PROVISIONAL REFERENCE CONCENTRATIONS

No adequate studies have been located regarding toxicity of BeP to humans via inhalation exposure. Identified studies included occupational studies in workers exposed to complex mixtures that lacked BeP-specific exposure data and case-control studies of asthma and lung cancer that did not find associations with biomarkers of BeP exposure. No animal studies of inhalation exposure to BeP were identified. As a result of the limitations of the available inhalation toxicity data for BeP, subchronic and chronic provisional reference concentrations (p-RfCs) were not derived directly. Instead, screening subchronic and chronic p-RfCs are derived in Appendix A using an alternative analogue approach. Based on the overall analogue approach presented in Appendix A, BaP was selected as the most appropriate analogue for BeP for deriving a screening subchronic and chronic p-RfC (see Table 5).

## 3.3 SUMMARY OF NONCANCER PROVISIONAL REFERENCE VALUES

A summary of the noncancer provisional reference values is shown in Table 5.

Table 5 Summary of Noncancer Reference Values for BeP (CASRN 192-97-2)

Toxicity Type (units) | Species/Sex | Critical Effect | p-Reference Value | POD Method | POD (HED/HEC) | UF_C_ | Principal Study
Screening subchronic p-RfD (mg/kg-d) | Rat/M, F | Neurodevelopmental changes following early postnatal exposure | 9 × 10^−5^ | BMDL_1SD_ | 0.092^a^; (based on analogue POD) | 1,000 | Chen et al. (2012) as cited in U.S. EPA (2017c)
Screening chronic p-RfD (mg/kg-d) | Rat/M, F | Neurodevelopmental changes following early postnatal exposure | 9 × 10^−5^ | BMDL_1SD_ | 0.092^a^; (based on analogue POD) | 1,000 | Chen et al. (2012) as cited in U.S. EPA (2017c)
Screening subchronic p-RfC (mg/m^3^) | Rat/F | Decreased embryo/fetal survival | 2 × 10^−6^ | LOAEL | 0.0046; (based on analogue POD) | 3,000 | Archibong et al. (2002) as cited in U.S. EPA (2017c)
Screening chronic p-RfC (mg/m^3^) | Rat/F | Decreased embryo/fetal survival | 2 × 10^−6^ | LOAEL | 0.0046; (based on analogue POD) | 3,000 | Archibong et al. (2002) as cited in U.S. EPA (2017c)

a The POD was not converted into an HED using BW^3/4^ because it is unknown whether allometric scaling is appropriate for exposure in early postnatal animals (see Appendix A for more details).

BeP = benzo[e]pyrene; BMDL = benchmark dose lower confidence limit; BW = body weight; F = female(s); HEC = human equivalent concentration; HED = human equivalent dose; LOAEL = lowest-observed-adverse-effect level; M = male(s); POD = point of departure; p-RfC = provisional reference concentration; p-RfD = provisional reference dose; SD = standard deviation; UF_C_ = composite uncertainty factor.

## 3.4 CANCER WEIGHT-OF-EVIDENCE DESCRIPTOR

Although the scientific literature provides information on the mutagenicity and genotoxicity of BeP, no oral or inhalation studies have been conducted to assess its carcinogenicity. Available dermal, lung implantation, and i.p. carcinogenicity studies in animals suggest that BeP has some carcinogenic potential, although findings are inconsistent across studies, and the relevance of these findings to oral or inhalation exposure is unclear. Under the U.S. EPA Cancer Guidelines (U.S. EPA, 2005), there is “Inadequate Information to Assess Carcinogenic Potential” of BeP by oral or inhalation exposure (see Table 6). Within the current U.S. EPA Cancer Guidelines (U.S. EPA, 2005), there is no standard methodology to support the identification of a weight-of-evidence (WOE) descriptor and derivation of provisional cancer risk estimates for data-poor chemicals using an analogue approach. In the absence of an established framework, a screening evaluation of potential carcinogenicity is provided using the methodology described in Appendix B. This evaluation determined that there was a qualitative level of concern for potential carcinogenicity for BeP (see Appendix C).

Table 6 Cancer WOE Descriptor for BeP (CASRN 192-97-2)

Possible WOE Descriptor | Designation | Route of Entry (oral, inhalation, or both) | Comments
“Carcinogenic to Humans” | NS | NA | No human data are available.
“Likely to Be Carcinogenic to Humans” | NS | NA | No adequate chronic-duration animal cancer bioassays are available.
“Suggestive Evidence of Carcinogenic Potential” | NS | NA | No adequate chronic-duration animal cancer bioassays are available.
“Inadequate Information to Assess Carcinogenic Potential” | Selected | Both | No adequate animal cancer bioassays are available. Dermal, lung implantation, and i.p. studies in animals provide limited evidence of carcinogenic potential.
“Not Likely to Be Carcinogenic to Humans” | NS | NA | No evidence of noncarcinogenicity is available. No adequate chronic-duration animal cancer bioassays are available.

BeP = benzo[e]pyrene; i.p. = intraperitoneal; NA = not applicable; NS = not selected; WOE = weight of evidence.

## 3.5 DERIVATION OF PROVISIONAL CANCER RISK ESTIMATES

The absence of suitable data precludes development of cancer risk estimates for BeP (see Table 7).

Table 7 Summary of Cancer Risk Estimates for BeP (CASRN 192-97-2)

Toxicity Type (units) | Species/Sex | Tumor Type | Cancer Risk Estimates | Principal Study
p-OSF (mg/kg-d)^−1^ | NDr
p-IUR (mg/m^3^)^−1^ | NDr

BeP = benzo[e]pyrene; NDr = not determined; p-IUR = provisional inhalation unit risk; p-OSF = provisional oral slope factor.