# 2 REVIEW OF POTENTIALLY RELEVANT DATA (NONCANCER AND CANCER)

As summarized in Tables 3A and 3B, no short-term, subchronic, or chronic studies as well as reproductive and developmental toxicity studies of BeP in humans or animals exposed by oral or inhalation routes adequate for deriving provisional toxicity values have been identified. The phrase “statistical significance” and term “significant,” used throughout the document, indicate a p-value of < 0.05 unless otherwise specified.

Table 3A Summary of Potentially Relevant Noncancer Data for BeP (CASRN 192-97-2)

Category | Number of Male/Female, Strain, Species, Study Type, Reported Doses, Study Duration | Dosimetry | Critical Effects | NOAEL | LOAEL | Reference (comments) | Notes
Human
1. Oral (mg/kg-d)
ND
2. Inhalation (mg/m^3^)
ND
Animal
1. Oral (mg/kg-d)
ND
2. Inhalation (mg/m^3^)
ND

BeP = benzo[e]pyrene; LOAEL = lowest-observed-adverse-effect level; ND = no data; NOAEL = no-observed-adverse-effect level.

Table 3B Summary of Potentially Relevant Cancer Data for BeP (CASRN 192-97-2)

Category | Number of Male/Female, Strain, Species, Study Type, Reported Doses, Study Duration | Dosimetry | Critical Effects | Reference (comments) | Notes
Human
1. Oral (mg/kg-d)
ND
2. Inhalation (mg/m^3^)
ND
Animal
1. Oral (mg/kg-d)
ND
2. Inhalation (mg/m^3^)
ND

BeP = benzo[e]pyrene; ND = no data.

## 2.1 HUMAN STUDIES

### 2.1.1 Oral Exposures

No studies have been identified.

### 2.1.2 Inhalation Exposures

No studies have been identified.

## 2.2 ANIMAL STUDIES

### 2.2.1 Oral Exposures

No studies have been identified.

### 2.2.2 Inhalation Exposures

No studies have been identified.

## 2.3 OTHER DATA (SHORT-TERM TESTS, OTHER EXAMINATIONS)

Available toxicity data for BeP include human occupational studies of exposure to complex mixtures that are of limited use for hazard identification and do not provide adequate exposure data for dose-response assessment. Two case-control studies found no associations between asthma or lung cancer incidence and serum BeP concentrations following BeP exposure. There is one subchronic study in apolipoprotein E knockout (apoE-KO) mice and two studies in avian models evaluating atherosclerosis. An acute oral study evaluated biochemical markers of hepatic damage. There are also dermal and injection studies evaluating immunotoxicity and carcinogenicity. Other available data include in vitro assays evaluating immunotoxic potential and retinal cell damage, genotoxicity assays, and toxicokinetic studies. Because the overall database for BeP was determined to be inadequate for direct derivation of oral or inhalation reference values, supporting studies described below were not considered for point of departure (POD) identification.

### 2.3.1 Genotoxicity

The genotoxicity of BeP has been evaluated in numerous in vitro studies and in a limited number of in vivo studies. Available studies are summarized below (see Table 4A for more details). The data indicate that BeP has mutagenic activity following metabolic activation and is not mutagenic in the absence of activation. In general, BeP did not cause chromosomal damage in vitro; however, findings from in vivo studies are mixed and suggest that, under certain conditions, BeP can cause chromosomal damage. BeP (or a metabolite) forms DNA adducts; however, most available in vitro and in vivo studies do not indicate that BeP alters DNA damage/synthesis/repair.

#### Mutagenicity

Of the available mutagenicity studies in Salmonella typhimurium, 15/20 reported that BeP was positive following metabolic activation in one or more strains (see Table 4A). In general, BeP yielded borderline or relatively low mutation rates compared with other mutagens (e.g., other PAHs) (Zeiger et al., 1992; De Flora et al., 1984; Dunkel et al., 1984; Haas et al., 1981; Kaden et al., 1979; Simmon, 1979; Wood et al., 1979; Andrews et al., 1978; McCann et al., 1975). One experiment that reported negative results for BeP with metabolic activation was part of a larger study comparing the results of experiments from four separate laboratories using the same protocol. The other three experiments all found positive results (Dunkel et al., 1984). Of the remaining studies, BeP was not mutagenic when metabolic activation was from liver homogenates of rats pretreated with phenobarbital (Teranishi et al., 1975) or corn oil, BeP, or tetrachlorodibenzo-p-dioxin (TCDD) (Ma et al., 1991) as alternatives to the standard Arochlor-induced S9 liver fraction. In the absence of metabolic activation, BeP was consistently reported as nonmutagenic in S. typhimurium (Cherng et al., 1996; Zeiger et al., 1992; Sakai et al., 1985; White et al., 1985a; Dunkel et al., 1984; Salamone et al., 1979; Simmon, 1979). BeP was not mutagenic in Escherichia coli with or without metabolic activation (Dunkel et al., 1984).

Table 4A Summary of BeP (CASRN 192-97-2) Genotoxicity

Endpoint | Test System | Doses/Concentrations Tested | Results without Activation^a^ | Results with Activation^a^ | Comments | References
Genotoxicity studies in prokaryotic organisms
Mutation | Salmonella typhimurium TA100 | 0, 1, 2.5, 5, 10, 25, 50, 100, 250, 500, 1,000 µg/plate | NS | + | Plate incorporation method. Criterion for positive response was dose-response (significant linear regression). The study authors reported that BeP was positive with S9 activation. The number of revertants was increased >twofold at 1,000 µg with S9 activation (data not reported for lower doses). Results without metabolic activation were not specified. | Andrews et al. (1978)
Mutation | S. typhimurium TA98, TA100, and TA104 | 0, 0.1, 0.5, 1.0, 2.5, 5.0, 10 µg/plate | NDr | +; (TA100); –; (TA98, TA104) | Plate incorporation method. Criterion for positive response was not reported.^b^ Metabolic activation was tested at three S9 concentrations (0.08, 0.22, and 0.95 mg/plate). Based on graphically presented data, the number of revertants was increased >twofold at 10 µg/plate at the highest S9 concentration in TA100 only. | Ball et al. (1991)
Mutation | S. typhimurium TA98 | 0, 25, 50, 100, 200 nmol/plate | – | NDr | Plate incorporation method. Criterion for positive response was not reported.^b^ No evidence of mutagenicity without metabolic activation. A positive control was not used (primary purpose of study was to evaluate influence of PAHs on mutagenicity of 1-nitropyrene). | Cherng et al. (1996)
Mutation | S. typhimurium TA97, TA98, TA100, TA1535, TA1537, TA1538 | Various dilutions using geometric ratio of 2, starting from solubility or toxicity limit | +; (TA98, TA100); ±; (TA97, TA1537); −; (TA1535, TA1538) | | Plate incorporation method. Criterion for positive response was >threefold increase in revertants (two- to threefold increase considered weak positive, 1.5- to twofold increase considered “reproducible,” <1.5-fold considered negative). Based on this criterion, TA98 and TA100 were positive, TA97 and TA1537 were “reproducible,” and TA1535 and TA1538 were negative; S9 activation increased mutagenicity. It is not clear from data presentation if reported fold-changes are with or without S9 activation. Mutagenetic potential in TA100 = 1.6 revertants/nmol with S9 activation. | De Flora et al. (1984)
Mutation | S. typhimurium TA98, TA100, TA1535, TA1537, TA1538 | 0, 0.3, 1.0, 3.3, 10.0, 33.3, 100.0, 333.3 µg/plate | – | +; (TA98, TA100, TA1538); ±; (TA1535); –; (TA1537) | Plate test. IRI laboratory. All strains tested with metabolic activation (using rat [R], mouse [M], and hamster [H] liver S9; either uninduced [U] or Arochlor induced [I]) and without activation. Criterion for positive response was ≥twofold increase at two or more doses; ≥twofold increase in revertants at only one dose was considered equivocal.; BeP was positive with metabolic activation in TA98 (RI), TA100 (RI), and TA1538 (HU) and equivocal with metabolic activation in TA1535 (MU). No evidence of mutagenicity without metabolic activation. | Dunkel et al. (1984)
Mutation | S. typhimurium TA98, TA100, TA1535, TA1537, TA1538 | 0, 0.3, 1.0, 3.3, 10.0, 33.3, 100.0, 333.3 µg/plate | – | – | Plate test. LBI laboratory. All strains tested with metabolic activation (RU, RI, MU, MI, HU, HI) and without activation. Criterion for positive response was ≥twofold increase at two or more doses; ≥twofold increase in revertants at only one dose was considered equivocal.; No evidence of mutagenicity with or without metabolic activation. Results for positive controls (sodium azide, 9-aminoacridine, 2-nitrofluorene, 2-aminoanthracene) were as expected. | Dunkel et al. (1984)
Mutation | S. typhimurium TA98, TA100, TA1535, TA1537, TA1538 | 0, 0.3, 1.0, 3.3, 10.0, 33.3, 100.0, 333.3 µg/plate | – | +; (TA98); ±; (TA1537, TA1538); –; (TA100, TA1535) | Plate test. NYM laboratory. All strains tested with metabolic activation (RU, RI, MU, MI, HU, HI) and without activation. Criterion for positive response was ≥twofold increase at two or more doses; ≥twofold increase in revertants at only one dose was considered equivocal.; BeP was positive with metabolic activation in TA98 (RI) and equivocal with metabolic activation in TA1537 (MI) and TA1538 (HU). No evidence of mutagenicity without metabolic activation. | Dunkel et al. (1984)
Mutation | S. typhimurium TA98, TA100, TA1535, TA1537, TA1538 | 0, 0.3, 1.0, 3.3, 10.0, 33.3, 100.0, 333.3 µg/plate | – | +; (TA98, TA100, TA1537); ±; (TA1538); –; (TA1535) | Plate test. SRI laboratory. All strains tested with metabolic activation (RU, RI, MU, MI, HU, HI) and without activation. Criterion for positive response was ≥twofold increase at two or more doses; ≥twofold increase in revertants at only one dose was considered equivocal.; BeP was positive with metabolic activation in TA98 (RI, MU), TA100 (RI) and TA1537 (MI) and equivocal with metabolic activation in TA1538 (MI). No evidence of mutagenicity without metabolic activation. | Dunkel et al. (1984)
Mutation | S. typhimurium TA98, TA100 | 0.2−2.5 µg/plate (TA98); 0.2−1.5 µg/plate (TA100) | NDr | +; (TA100); –; (TA98) | Plate incorporation method. Criterion for positive response was not reported, but the study authors reported a “significant” mutagenic response in TA100 with S9 activation. No evidence of mutagenicity in TA98 with S9 activation. | Haas et al. (1981)
Mutation | S. typhimurium TM677 | NS | NDr | + | 8-Azaguanine resistance forward mutation assay. Criterion for positive response was ≥3 SDs from the background mean. A positive response was observed at ≥90 µM with S9 activation. | Kaden et al. (1979)
Mutation | S. typhimurium TA98, TA100 | 0, 10, 20 µg/plate | NDr | +; (TA100); –; (TA98) | Plate incorporation method. Criterion for positive response was not reported.^b^ Revertants increased >twofold in TA100 with S9 activation. No evidence of mutagenicity in TA98 with S9 activation. | Lavoie et al. (1979)
Mutation | S. typhimurium TA100 | 10−333 µg/plate | NDr | – | Plate incorporation method. Criterion for positive response was reversion frequency >2 times the spontaneous rate. BeP was negative with metabolic activation using liver homogenates from mice pretreated with corn oil, BeP, or TCDD. | Ma et al. (1991)
Mutation | S. typhimurium TA100 | NS | NDr | + | Plate incorporation method. Criterion for positive response was >0.1 revertants/mol, weak response was <0.1 but >0.01 revertants/mol, and negative response was <0.01 revertants/mol. BeP mutation rate with S9 activation was 0.60 revertants/nmol (143 revertants/60 µg tested). | McCann et al. (1975)
Mutation | S. typhimurium TA1535, TA1537, TA1538, TA98, TA100 | 0.1−1,000 µg/plate | –; (TA100) | ±; (TA100) | Plate incorporation method. Criterion for positive response was >twofold increase in revertants. A twofold increase in revertants was observed in TA100 with S9 activation. Mutagenic response was reported as highest in TA100; number of revertants/plate not reported for other strains. | Salamone et al. (1979)
Mutation | S. typhimurium TA97, TA98, TA100 | 0, 5, 10, 50, 250 µg/plate | – | + | Plate incorporation method. Criterion for positive response was not reported.^b^ Revertants increased >twofold in all strains with S9 activation. No evidence of mutagenicity without S9 activation. | Sakai et al. (1985)
Mutation | S. typhimurium TA1535, TA1536, TA1537, TA1538, TA98, TA100 | ≤50 µg/plate | – | +; (TA1538, TA98, TA100); –; (TA1535, TA1536, TA1537) | Plate incorporation method. Criterion for positive result was a reproducible, dose-related increase in the number of revertants. A positive result was observed for TA1538, TA98, and TA100 with S9 activation. No evidence of mutagenicity without S9 activation. | Simmon (1979)
Mutation | S. typhimurium TA1535, TA1536, TA1537, TA1538 | 0, 50 µg/plate | NDr | – | Plate incorporation method. Criterion for positive response was a significant increase in the number of revertants. BeP was negative with metabolic activation using liver homogenates from rats pretreated with phenobarbital. A positive control was not used, but other tested PAHs induced significant increases in the number of revertants. | Teranishi et al. (1975)
Mutation | S. typhimurium TA98, TA100 | 10 nmol/plate | NDr | ± | Plate incorporation method. Criterion for positive response was not reported, but BeP was reported as weakly mutagenic in TA100 with S9 activation (rat liver microsomes), although not when incubated with purified rat hepatic CYP450. BeP was also weakly mutagenic in TA98 when activated by purified rat hepatic CYP450, but not S9. | Wood et al. (1979)
Mutation | S. typhimurium TA98 and its NR-deficient strains TA98NR and TA98/I,8-DNP6 | 0, 10 µg/plate | – | NDr | Plate incorporation assay. Criterion for positive response was ≥twofold increase in revertants. Mutagenic potential tested with and without irradiation (artificial sunlight or cool-white light). No evidence of mutagenicity with or without irradiation. Positive control (BaP) produced expected increase in revertants without irradiation (not tested with irradiation). | White et al. (1985a)
Mutation | S. typhimurium TA98, TA100 | 0, 3.3, 10, 33, 100, 333, 1,000, 2,000 µg/plate | – | + | Preincubation assay. Criterion for a positive response was a reproducible, dose-related response in replicate trials. BeP was positive in TA98 and TA100 with rat S9 activation. No evidence of mutagenicity without metabolic activation or with hamster S9 activation. | Zeiger et al. (1992)
Mutation | Escherichia coli WP2 uvrA | 0, 0.3, 1.0, 3.3, 10.0, 33.3, 100.0, 333.3 µg/plate | – | – | Plate test. E. coli was tested with metabolic activation (RU, RI, MU, MI, HU, HI) and without activation at four separate laboratories (IRI, LBI, NYM, SRI).; All laboratories: No evidence of mutagenicity with or without metabolic activation. | Dunkel et al. (1984)
DNA repair | E. coli WP2, WP67, C871 | ≤50 µg (eight twofold dilutions) | – | – | Liquid micromethod. The minimal inhibitory concentration was >50 µg with or without S9 activation. | De Flora et al. (1984)
DNA repair | E. coli WP2, WP67, C871 | ≤50 µg/10^3^ bacteria | – | ± | 2-h preincubation assay (treat-and-plate method). Survival did not differ between repair-deficient and wild-type strains without metabolic activation. Findings were equivocal with S9 activation. | De Flora et al. (1984)
DNA damage | E. coli PQ37 | 0, 0.156, 0.625, 2.5, 10.0 µg/assay | – | ± | SOS chromotest. 1.9-fold increase in DNA damage with S9 activation (>twofold considered positive). Findings were negative without S9 activation. | Mersch-Sundermann et al. (1993); Mersch-Sundermann et al. (1992)
Genotoxicity studies in mammalian cells—in vitro
Mutation | Human B-lymphoblastoid cells (h1A1v2); RPMI 1640 medium with 9% horse serum | 0, 10, 100, 1,000, 10,000 ng/mL | + | NDr | Forward mutation assay (thymidine kinase locus). A twofold increase in mutations was observed at 10,000 ng/mL; this dose was associated with 33% cytotoxicity. The minimum mutagenic concentration was calculated to be 8,000 ng/mL (dose that exceeds the 99% upper confidence limit of historical negative control). No exogenous metabolic activation was used, but h1A1v2 cells constitutively express cytochrome P4501A1. | Durant et al. (1996)
Mutation | Adult rat liver epithelial (ARL18) cells; culture media NS | 0, 100 μM | – | NDr | Hgprt forward mutation assay. No evidence of mutagenicity without exogenous metabolic activation (ARL18 cells have endogenous metabolic capabilities). Cell survival was not reported. | Ved Brat et al. (1983)
Mutation | Chinese hamster lung fibroblast (V79 cells); Eagle’s medium and 5−10% FBS | 0, 1 µg/mL | NDr | – | Cell-mediated mutagenesis assay. No evidence of mutagenicity with metabolic activation (V79 cells were co-cultured with metabolically competent rodent cells to produce reactive metabolites during exposure). Cell survival was not reported. | Huberman (1977)
SCE | Adult rat liver epithelial (ARL18) cells; culture media NS | 0, 10 μM | – | NDr | No evidence of SCE induction without exogenous activation (ARL18 cells have endogenous metabolic capabilities). | Ved Brat et al. (1983)
SCE | SHE cells; DMEM with 0, 10, or 40% FBS | 0, 0.1 µg/mL | ± | NDr | SHE cells were exposed to 10 µg BeP for 24 hours; postexposure, the organic phase was extracted to the culture medium and added to V79 cells (BeP was not metabolized by SHE cells during organic phase). A 1.4-fold increase in SCEs was observed when cells were exposed to organic phase extraction with 0% serum in the media; SCE induction was prevented with 10−40% FBS in the media. The study authors propose the observed decrease in cellular uptake was due to binding of BeP to serum proteins. | Coulomb et al. (1981)
SCE | Chinese hamster V79 cells; serum-free M199 medium | 0, 1 µg/mL | – | – | No induction of SCEs with or without metabolic activation (V79 cells were cocultured with metabolically competent rat mammary epithelial cells to produce reactive metabolites during exposure). | Mane et al. (1990)
MN | Wistar rat skin fibroblasts (UGT-normal or UGT-deficient); DMEM with 13% FBS | 0, 10 µM | −; (UGT-deficient) | –; (UGT-normal) | No induction of MN in UGT-normal or UGT-deficient fibroblasts. | Vienneau et al. (1995)
DNA damage | Human skin fibroblasts; MEM with 20% FBS | 0, 13 μM | – | NDr | No significant induction of DNA breaks. | Milo et al. (1978)
DNA damage | Chinese hamster V79 cells; DMEM with 5% FBS | 0, 10, 20, 50, 100 µM | + | NDr | Comet test (alkaline version). DNA strand breaks increased >twofold without metabolic activation at 100 µM. | Platt et al. (2008)
DNA synthesis | Human skin fibroblasts; MEM with 20% FBS | 0, 13 μM | – | NDr | ^3^HTdR incorporation assay. No significant inhibition of scheduled DNA synthesis. | Milo et al. (1978)
DNA synthesis | Rat mammary epithelial cells; serum-free M199 medium | 5 µg/mL | – | NDr | ^3^HTdR incorporation assay. No significant inhibition of scheduled DNA synthesis. | Mane et al. (1990)
DNA synthesis | F344 rat hepatocytes; MEM with 25% HPRS | 0, 1, 10, 100 μM | – | NDr | ^3^HTdR incorporation assay. No significant inhibition of scheduled DNA synthesis. | Novicki et al. (1985)
DNA synthesis | Sprague Dawley rat hepatocytes; L-15 medium with 10% FBS | 0, 1, 100, 1,000 nM | – | NA | ^3^HTdR incorporation assay. No significant inhibition of scheduled DNA synthesis. | Zhao and Ramos (1995)
UDS | Adult rat hepatocytes; serum-free William’s medium E | ≤100 nmol/mL | – | NDr | Hepatocyte primary culture-DNA repair test. No evidence of increased UDS in the absence of exogenous metabolic activation (hepatocytes are metabolically competent). | Probst et al. (1981)
UDS | Adult mouse lung fibroblasts; DMEM with 10% FBS | 0, 1, 10, 100 µM | – | – | No evidence of increased UDS with or without S9 activation. | Schmitt et al. (1984)
UDS | SHE cells; serum- and arginine-free medium | 0, 2.5, 5, 10, 20 µg/mL | – | NDr | No evidence of increased UDS. | Casto et al. (1976)
UDS | Syrian hamster tracheal organ cultures; serum-free CMRL medium 1066 | 0, 0.1, 1.0 µg/mL | – | NDr | No evidence of increased UDS in the absence of exogenous metabolic activation (tracheal organ cultures are metabolically competent). | Schiff et al. (1983)
Cell transformation | SHE cells; DMEM with 10% FBS | 0, 10 µg/mL | ± | NDr | BeP treatment produced 0.6% transformation and was considered “slightly effective.” Cloning efficiency (6.8%) was comparable to control (7.0%). | DiPaolo et al. (1969)
Genotoxicity studies—in vivo
CA (bone marrow) | Female Long-Evans rats exposed to BeP via i.v. infusion and sacrificed 24 h postinjection | 0, 40 mg/kg | + | NA | >Threefold increase in chromosomal breaks at 24 h postinjection. | Rees et al. (1970)
CA (bone marrow) | Male and female Chinese hamsters were exposed to BeP via i.p. injection; hamsters were administered two injections, 24 h apart; hamsters were sacrificed 24 h after 2nd injection | 0, 450 mg/kg | – | NA | No significant induction of CAs. | Roszinsky-Köcher et al. (1979)
SCE (bone marrow) | Male and female Chinese hamsters were exposed to BeP via i.p. injection; hamsters were administered two injections, 24 h apart; hamsters were sacrificed 24 h after 2nd injection | 0, 450 mg/kg | + | NA | Significant 1.4-fold increase in SCEs per metaphase. | Roszinsky-Köcher et al. (1979)
MN (bone marrow) | Female mice (C57BL/6, BALB/c, DBA/2, BDF1, and CDF1 hybrids) were exposed once to BeP via i.p. injection and sacrificed 24, 48, or 72 h postinjection | 0, 100 mg/kg | – | NA | No significant induction of MN in any mouse strain at any time point. | Sato et al. (1987)
DNA damage (liver) | Female Sprague Dawley rats exposed twice to BeP via gavage in corn oil; the 1st dose was administered 21 h prior to sacrifice and the 2nd dose was administered 4 h prior to sacrifice | 0, 18 mg/kg | – | NA | Alkaline elution assay. No significant hepatic DNA damage. | Kitchin et al. (1993); Kitchin et al. (1992)
DNA synthesis (thymus, spleen, bone marrow) | Male Wistar rats exposed to BeP via i.p. injection in olive oil and sacrificed at 24 and 48 h postinjection. ^3^HTdR i.m. injections given 30 min prior to sacrifice | 0.19 µmol/g | + | NA | ^3^HTdR incorporation analysis. DNA synthesis was significantly decreased by 64.5−67.8% in thymus and 31.0−50.3% in spleen at 24- and 48-h postexposure. DNA synthesis was significantly decreased by 21.2% in bone marrow at 24-h postexposure only. The study authors note that decreased ^3^HTdR incorporation may reflect cytotoxicity instead of decreased DNA synthesis. | Prodi et al. (1975)
DNA synthesis (liver) | Male Wistar rats exposed to BeP via i.p. injection in olive oil 2 h after a partial hepatectomy; rats sacrificed 22 h postexposure; ^3^HTdR i.m. injections given 30 min prior to sacrifice | 0.19 µmol/g | + | NA | ^3^HTdR incorporation analysis. DNA synthesis was significantly decreased by 39.4% in regenerating liver following BeP exposure. The study authors note that decreased ^3^HTdR incorporation may reflect cytotoxicity instead of decreased DNA synthesis. | Prodi et al. (1975)
DNA adducts | Female BALB/c mice exposed to BeP via four topical applications at 0, 6, 30, and 54 h; sacrificed 24 h after last treatment | 1.2 µmol | + | NA | ^32^P-postlabeling analysis. Five adducts were detected in mouse skin at a level of 1 adduct per >10^7^ normal nucleotides. | Reddy et al. (1984)
Genotoxicity studies in invertebrates-in vivo
DNA repair | Drosophila melanogaster; Rec^−^ males and Rec^+^ females were exposed as larvae and scored as adults | Up to 100 mg/mL | – | NA | A reduction in Rec^−^ larvae would indicate DNA damage from the test compound. There was no significant reduction in the Rec^−^:Rec^+^ ratio. | Fujikawa et al. (1993)
Genotoxicity studies in subcellular systems
DNA adducts | Human DNA | 100 µM | NDr | + | ^32^P-postlabeling assay with nuclease P1 treatment or butanol extraction for enrichment of adducts. BeP adducts were detected with both procedures, but ~50% more adducts were detected with butanol extraction. | Segerbäck and Vodicka (1993)

a + = positive; ± = weakly positive/equivocal; – = negative.

b For bacterial mutagenicity studies that did not report criteria for positive results, an induction of revertants >twofold was considered positive for the purposes of this review.

^3^HTdR = [^3^H]Thymidine; BaP = benzo[a]pyrene; BeP = benzo[e]pyrene; CA = chromosomal aberration; CMRL = Connaught Medical Research Laboratories Medium 1066; CYP450 = cytochrome P450; DMEM = Dulbecco’s modified minimal essential medium; DNA = deoxyribonucleic acid; FBS = fetal bovine serum; HI = Arochlor-induced hamster liver S9 protein; HPRS = hepatectomized rat serum; HU = uninduced hamster liver S9 protein; i.m. = intramuscular; i.p. = intraperitoneal; IRI = Inveresk Research International; i.v. = intravenous; LBI = Litton Bionetics, Inc.; MEM = minimal essential medium; MI = Arochlor-induced mouse liver S9 protein; MN = micronuclei; MU = uninduced mouse liver S9 protein; NA = not applicable; NDr = not determined; NR = nitroreductase; NS = not specified; NYM = New York Medical College; PAH = polycylic aromatic hydrocarbon; RI = Arochlor-induced rat liver S9 protein; RU = uninduced rat liver S9 protein; SCE = sister chromatid exchange; SD = standard deviation; SHE = Syrian hamster embryo; SRI = SRI International; TCDD = 2,3,7,8-tetrachlorodibenzo-p-dioxin; UDS = unscheduled DNA synthesis; UGT = uridine 5′-diphospho-glucuronosyltransferase.

Mutagenicity findings in mammalian cells were negative at noncytotoxic concentrations. In metabolically competent human B-lymphoblastoid cells, forward mutations were induced at the thymidine kinase (tk) locus at a BeP concentration associated with >30% cytotoxicity (10,000 ng/mL); mutations were not observed at noncytotoxic concentrations ≤1,000 ng/mL (Durant et al., 1996). In other assays, BeP did not induce forward mutations in metabolically competent adult rat liver epithelial (ARL18) cells at the hypoxanthine-guanine phosphoribosyltransferase (Hgprt) locus (Ved Brat et al., 1983) or cell-mediated mutagenicity in Chinese hamster lung fibroblasts (V79 cells) cocultured with metabolically competent rodent cells (Huberman, 1977).

#### Clastogenicity

Evidence of clastogenicity from in vitro studies in mammalian cells is predominately negative. Coulomb et al. (1981) reported a weak induction of sister chromatid exchanges (SCEs) by BeP in Chinese hamster V79 cells in serum-free culture media, but not in media containing 10−40% fetal bovine serum (FBS). The study authors proposed that the presence or absence of serum in the media may influence test results, because dose-related decreases in cellular uptake of BeP by Syrian hamster embryo (SHE) cells were observed with increasing levels of FBS in culture media (possibly due to BeP binding to serum lipoproteins) (Coulomb et al., 1981). However, Mane et al. (1990) reported that SCEs were not induced by BeP in Chinese hamster V79 cells with or without metabolic activation in serum-free medium. SCEs were also not induced by BeP in metabolically competent ARL18 cells (culture medium composition not reported) (Ved Brat et al., 1983). Micronuclei (MN) were not induced by BeP in normal rat skin fibroblasts or uridine 5′-diphospho-glucuronosyltransferase (UGT)-deficient rat skin fibroblasts cultured with 13% FBS (Vienneau et al., 1995).

Evidence of clastogenicity from in vivo studies in rodents is mixed. BeP induced chromosomal aberrations (CAs) in rat bone marrow following a single intravenous (i.v.) injection of 40 mg/kg (Rees et al., 1970). And in hamsters, BeP induced SCEs (but not CAs) in bone marrow cells following a single i.p. injection of 450 mg/kg (Roszinsky-Köcher et al., 1979). In mice, BeP did not increase micronucleated erythrocytes in bone marrow following i.p. injection of 100 mg/kg (Sato et al., 1987).

#### DNA Damage and Repair

Findings were generally negative in in vitro assays of DNA damage and repair. In E. coli, BeP did not induce DNA damage or repair activity without metabolic activation; with activation, findings were negative or equivocal/borderline (Mersch-Sundermann et al., 1993; Mersch-Sundermann et al., 1992; De Flora et al., 1984). In mammalian cells, DNA strand breaks were reported in Chinese hamster V79 cells following exposure to BeP in media containing 5% FBS (Platt et al., 2008); however, DNA strand breaks were not induced by BeP in human skin fibroblasts in media containing 20% FBS (Milo et al., 1978). As discussed above, the higher levels of serum in the human cell assay could have affected test results due to decreased cellular uptake of BeP with increasing serum levels in culture media (Coulomb et al., 1981). Additionally, the presence of serum (a mitogen) may skew the utilization of alternative DNA damage-and-repair pathways that are only active in actively cycling cell populations. It is unclear how the use of different molecular DNA damage-and-repair pathways may influence the dynamics of these repair processes.

In other mammalian cell studies, BeP did not inhibit scheduled DNA synthesis in human or rat cells with serum present in the culture media or rat cells in the absence of serum (Zhao and Ramos, 1995; Mane et al., 1990; Novicki et al., 1985; Milo et al., 1978). Similarly, BeP did not induce unscheduled DNA synthesis in rat or hamster cells in serum-free media or in mouse lung fibroblasts in the presence of serum (Schmitt et al., 1984; Schiff et al., 1983; Probst et al., 1981; Casto et al., 1976).

Findings were also generally negative in in vivo assays of DNA damage and repair. Drosophila melanogaster did not show increased rates of DNA repair after exposure to BeP (Fujikawa et al., 1993). No evidence of hepatic DNA damage was observed in rats following two gavage doses of 18 mg/kg (Kitchin et al., 1993; Kitchin et al., 1992). Another rat study reported inhibited ^3^H-thymidine uptake in thymus, spleen, bone marrow, and regenerating liver 24−48 hours after i.p. exposure to BeP, suggesting decreased rates of DNA synthesis (Prodi et al., 1975). However, the study authors noted that findings may reflect general cytotoxicity of BeP, rather than decreased DNA synthesis.

DNA adducts were identified in mouse skin following repeated topical application of BeP to shaved skin (four exposures over 54 hours) (Reddy et al., 1984). Isolated human DNA has also been shown to form BeP DNA adducts in vitro (Segerbäck and Vodicka, 1993).

#### Cell Transformation

BeP was a weak inducer of cell transformation in SHE cells in the absence of metabolic activation in medium containing 10% FBS (DiPaolo et al., 1969).

### 2.3.2 Supporting Human Studies

Several occupational studies examined populations with exposures to multiple compounds in the absence of BeP-specific exposure analyses. These studies are of limited use for BeP hazard identification and do not provide data for dose-response analysis. Reported effects include subjective health complaints (skin irritation, headaches, shortness of breath, nausea, cough, phlegm) and altered markers of immune function in coke oven workers exposed to various PAHs in coal tar sludge and coal dust (Winker et al., 1997; NIOSH, 1987, 1986). Other effects include skin phototoxicity and skin and respiratory tract irritation in petroleum refining workers exposed to various PAHs in petroleum pitch (Vandervort and Lucas, 1974), impaired lung function (e.g., increased residual volume, reduced total lung capacity) in rubber factory workers exposed to suspended particulate matter containing various PAHs (Gupta et al., 1998; Gupta et al., 1994), and increased markers of oxidative deoxyribonucleic acid (DNA) damage in roofers exposed to various PAHs in hot asphalt (Serdar et al., 2016). Another study reported elevated biomarkers of chromosomal and DNA damage in nonsmoking female city hall clerks employed and living in the most polluted urban region of Silesia, Poland (high PAH exposure levels), compared with nonsmoking female controls living in a less polluted urban region of Białystok, Poland (low PAH exposure levels) (Motykiewicz et al., 1998).

In population-based, case-control studies, no significant differences were observed in serum BeP levels between control and asthmatic children in Saudi Arabia (Al-Daghri et al., 2014) or lung tissue BeP levels between patients with tuberculosis (control) and patients with lung carcinoma in 1961−1962 or 1991−1996 in Japan (Tokiwa et al., 1998).

### 2.3.3 Supporting Animal Studies

#### Acute Toxicity

Kitchin et al. (1993) and Kitchin et al. (1992) evaluated hepatic biochemical endpoints in female rats following acute oral exposure to BeP. The rats were exposed twice to BeP at 0 or 18 mg/kg via gavage in corn oil; the first dose was administered 21 hours prior to sacrifice and the second one 4 hours prior to sacrifice. All rats survived. No exposure-related changes in serum alanine aminotransferase (ALT) activity, hepatic ornithine decarboxylase activity, or hepatic cytochrome P450 (CYP450) content were observed.

#### Cardiovascular Toxicity

There is a body of evidence describing cardiotoxicity induced by environmentally relevant PAHs in non-human model systems (Brette et al., 2017). Specifically, there is concern that BeP may cause cardiovascular effects because the U.S. EPA (2017c) concluded that available animal studies for benzo[a]pyrene (BaP), a PAH with similar structure and physicochemical properties, provided suggestive evidence of cardiovascular toxicity (i.e., atherosclerosis). Curfs et al. (2005) conducted a study directly comparing BeP- and BaP-induced atherosclerotic plaque formation in mice genetically predisposed to develop plaques. Both compounds showed a similar capability to promote atherosclerosis. Following oral exposure to BaP or BeP (5 mg/kg-day) via once weekly gavage for 24 weeks, the location and total number of initial and advanced plaques (combined) per aortic arch were similar in treated and control mice, but the total area of advanced plaques/arch was significantly (p<0.05) increased by 1.4- to 1.5-fold in BaP- and BeP-treated mice compared with controls. In the thoracic aorta, there were no exposure-related changes in number or size of plaques; however, both BaP- and BeP-treated groups exhibited significantly increased plaque total inflammatory cells (CD45-positive cells) and plaque T lymphocytes (CD3-positive cells). The only clear difference between BaP- and BeP-treated mice was significant DNA-adduct formation in the lung of BaP-treated mice compared with BeP-treated and control mice. This suggests potential differences in distribution and/or potency in lung tissue; however, the relevance of this data to human PAH-mediated cardiotoxicity is unclear due to the use of transgenic knockout mice. Immunostaining for TGFβ1 in aortic arch plaques—a phenomenon observed in stable atherosclerotic lesions—was also increased in BaP- and BeP-treated groups compared with controls (Toma and McCaffrey, 2012). In contrast, in vitro treatment of the murine monocyte/macrophage RA W364.7 cell line with BaP or BeP revealed no apparent PAH treatment-related effect on release of tumor necrosis factor-alpha (TNF-α) or expression of transforming growth factor beta 1 (TGFβ1).

Avian models have also been used to study the promotion of atherosclerosis by PAH compounds. Penn and Snyder (1988) demonstrated that both BaP (40 mg/kg-day) and BeP (20 mg/kg-day) promoted atherosclerotic plaque development parameters in cockerels following weekly intramuscular (i.m.) injection for 16 weeks. A study in pigeons, however, reported an increase in aortic plaque size and number, for BaP only, following weekly i.m. injections of 100 mg/kg BaP or BeP for 3 or 6 months (Revis et al., 1984).

#### Immunotoxicity

The immunotoxic potential of BeP has been evaluated in numerous in vivo and in vitro studies (see Table 4B for more details). Most of the in vivo studies reported lack of immunosuppressive effects of BeP on parameters of humoral or cell-mediated immunity in mice or rats given BeP via subcutaneous (s.c.) or intraperitoneal (i.p.) injection. Effects measured included antibody responses to antigens (Munson and White, 1992, 1986; White et al., 1985b; White and Holsapple, 1984; Dean et al., 1983; Munson and White, 1983); delayed hypersensitivity (White et al., 2012; Munson and White, 1992, 1986, 1983); lymphoproliferative response to mitogens (Munson and White, 1992; Wojdani and Alfred, 1984; Dean et al., 1983; Munson and White, 1983); macrophage function (Munson and White, 1992, 1983); host resistance to bacteria, viruses, or tumor cells (Munson et al., 1985); and cell-mediated cytotoxicity (Wojdani and Alfred, 1984; Wojdani et al., 1984). Exposure to BeP reduced the T cell-dependent antibody response to sheep red blood cells (sRBCs) in spleen cells cultured from exposed mice in one study (Blanton et al., 1986). Each of these studies compared the response of BeP to the immunosuppressive response of the canonical PAH BaP administered at the same dose levels (highest dose of 40 mg/kg-day). It is unclear whether BeP would have elicited an immunosuppressive response if administered at higher doses. Dermal exposure to BeP was shown to elicit a contact hypersensitivity response in mouse skin (Anderson et al., 1995).

In vitro studies provided some evidence of BeP immunotoxicity, including inhibition of mitogenesis in human lymphocytes (Davila et al., 1996) and decreased B-cell lymphopoiesis in murine bone marrow (Hardin et al., 1992). Inconsistent findings, however, were reported for inhibition of T-cell and B-cell antibody responses in mouse spleen cells (Blanton et al., 1986; White and Holsapple, 1984), and no effect was reported after BeP exposure on the differentiation of human monocytes into macrophages (van Grevenynghe et al., 2003). Mechanistic studies have investigated the possible involvement of altered protein tyrosine kinase activity, calcium uptake and/or retention, glutathione (GSH) depletion, or aryl hydrocarbon hydrolase (AHH) activity; however, no clear relationship between these parameters and BeP immunotoxicity was reported (Davila et al., 1999; Romero et al., 1997; Krieger et al., 1995; Krieger et al., 1994; Gurtoo et al., 1979).

Table 4B Immunotoxicity Studies of BeP (CASRN 192-97-2)

Test | Materials and Methods | Results | Conclusions | References
In vivo animal studies
Contact hypersensitivity | C3H/HeN mice (3−5/group, sex not reported); 1,000 µg BeP was applied to the shaved abdominal skin (covered by permeable membrane); 5 d later, 200 µg BeP was applied to the dorsal aspect of the ear; ear thickness was measured immediately following challenge and daily thereafter for up to 5 d; negative controls received challenge application only; AHH activity was measured in microsomes isolated from abdominal skin of two mice 24 h following application of 1,000 µg BeP. | Maximum ear thickness was increased by 3.2 × 10^−2^ mm over negative controls; AHH activity was 5% higher than controls. | BeP produced a contact hypersensitivity response in mouse skin but was a poor inducer of AHH activity. | Anderson et al. (1995)
T cell-dependent and independent antibody responses | Female B6C3F1 mice (number per group not reported) received daily s.c. injections containing 0 (polyvinylpyrrolidone vehicle) or 40 mg/kg-d for 7 or 14 d; spleen cell responses to sRBCs or LPS were measured in culture (measured as PFCs). | Response to sRBCs was reduced by 48% at 7 d and 51% at 14 d; slight inhibition of antibody response to LPS (data not shown). | Exposure to BeP reduced the T cell-dependent antibody response to sRBCs in spleen cells cultured from exposed mice; inhibition of the B cell-mediated antibody response was minimal. | Blanton et al. (1986)
T cell-dependent and independent antibody responses; lymphoproliferative response to mitogens | Female B6C3F1 mice (6−10/group per assay) received daily s.c. injections containing 0 (corn oil vehicle), 5, 20, or 40 mg/kg-d for 14 d; parameters evaluated included body and organ weights, histopathology, hematology, antibody PFC response to sRBCs and LPS administered intravenously, and lymphoproliferative responses to mitogens (PHA, LPS). | No effects on body or organ weights or hematological parameters; no effects on antibody PFC responses or lymphoproliferative responses to mitogens. | BeP did not affect the T cell-dependent antibody response to sRBCs, the B-cell response to LPS, or the lymphoproliferative response to mitogens in mice. | Dean et al. (1983)
Multiple assays of humoral and cell-mediated immunity and macrophage function | Male and female B6C3F1 mice (72−140/sex/group) received daily s.c. injections containing 0 (corn oil vehicle), 5, 20, or 40 mg/kg-d for 14 d; endpoints evaluated included body and organ weights, hematology, humoral immunity evaluations (spleen IgM response to sRBCs, serum immunoglobulins and complement, and spleen B-cell response to LPS), cell-mediated immunity evaluations (delayed hypersensitivity response to KLH and sRBCs, popliteal lymph node response to sRBCs, spleen T-cell response to Con A and acute inflammatory response to carrageenan), and macrophage function (vascular clearance and uptake of radiolabeled sRBCs). | Absolute and relative liver weights increased by 19 and 7%, respectively, in males at 40 mg/kg-d; absolute spleen weight increased by 26 and 18% in males at 20 and 40 mg/kg-d, respectively; absolute spleen weight decreased by 36% in females at 40 mg/kg-d (no changes in relative spleen weight); and relative lung weight decreased by 11−12% in males at all doses (no change in absolute lung weight). Leukocyte count decreased by 68% in males at 40 mg/kg-d. No other significant treatment-related effects were observed. | BeP did not impair humoral immunity, cell-mediated immunity, or macrophage function in mice. | Munson and White (1992); Munson and White (1983); Munson and White (1983) (unpublished)
Host resistance assays | Female B6C3F1 mice (8/group) received daily s.c. injections containing 0 (corn oil vehicle) or 40 mg/kg-d for 14 d; Listeria monocytogenes, Streptococcus pneumoniae, herpes simplex type 2, influenza A2, or B16F10 melanoma cells injected on Day 15 (four concentrations of each pathogen); host resistance measured as percent mortality or incidence and multiplicity of tumors. | No change in mortality incidence in response to L. monocytogenes, S. pneumoniae, herpes simplex type 2, or influenza A2; no change in tumor incidence and multiplicity following injection of B16F10 melanoma cells. | BeP did not alter host resistance to bacteria, viruses, or tumor cells in mice. | Munson et al. (1985) (unpublished)
T cell-dependent antibody response and delayed hypersensitivity response | Male F344 rats (8/group) received daily s.c. injections containing 0 (corn oil vehicle) or 20 mg/kg-d for 14 d; parameters evaluated included body and organ weights, hematology, spleen IgM response to sRBCs, and delayed hypersensitivity response to KLH. | No change in body weight; 18% increase in relative liver weight (no other organ-weight changes); 26% decrease in leukocytes, 67% decrease in monocytes; no change in the spleen IgM response to sRBCs; and no change in the delayed hypersensitivity response to KLH and sRBCs. | BeP did not alter T cell-dependent antibody response to sRBCs or the delayed hypersensitivity response to KLH or sRBCs. | Munson and White (1986) (unpublished)
T cell-dependent antibody response | Female B6C3F1 mice (8/group) received daily s.c. injections containing 0 (corn oil vehicle), 5, 20, or 40 mg/kg-d for 14 d; spleen IgM response was evaluated 4 d after injection with sRBCs (PFCs). | No change in the spleen IgM response to sRBCs. | BeP did not impair humoral immunity in mice. | White and Holsapple (1984)
T cell-dependent antibody response | Female B6C3F1 mice (8/group) received daily s.c. injections containing 0 (corn oil vehicle) or 40 mg/kg-d (160 µmol/kg-d) for 14 d; spleen IgM response was evaluated 4 d after injection with sRBCs (spleen weight, cellularity, and number of PFCs). | No change in the spleen IgM response to sRBCs. | BeP did not impair humoral immunity in mice. | White et al. (1985b)
Candida albicans DTH test | Female B6C3F1 mice (7−8/group) received daily s.c. injections containing 0 (corn oil vehicle), 5, 20, or 40 mg/kg-d for 28 d; the C. albicans DTH test was performed; C. albicans was injected into the right flank of mice on Day 21; mice were challenged with injection of C. albicans antigen (chitosan) into the right footpad; footpad thickness was measured pre- and postchallenge. | BeP did not increase footpad swelling above vehicle controls. | BeP did not impair cell-mediated immunity in mice. | White et al. (2012)
Multiple assays of cell-mediated immunity | C3H, C57BL/6, and DBA mice (6/group; sex not reported) were given an i.p. injection of PHA; 96 h later, BeP was administered by i.p. injection at doses of 0 (corn oil), 2.5, 10, or 50 mg/kg; mice were sacrificed 24 h later; cell-mediated immunity parameters included blastogenesis of splenic lymphocytes, cell-mediated cytotoxicity (percent ^51^Cr release from target cells), and percent of monocyte-macrophages in spleen cell suspensions. | BeP did not induce lymphoblastogenesis or increase cell-mediated cytotoxicity or the percent monocyte-macrophages in spleen cell suspensions. | BeP did not impair cell-mediated immunity in mice. | Wojdani and Alfred (1984)
Cytotoxic lymphocyte response | C3H and C57BL/6 mice (6/group, sex not reported) were preimmunized with P815 tumor cells (i.p.) and treated 10 d later with a single i.p. injection of BeP at doses of 0 (corn oil), 0.5, 5, or 50 mg/kg; after 24 h, splenic lymphocytes and peritoneal exudate lymphocytes were isolated and used to measure binding and killing of P815 target cells. | BeP reduced percent binding and percent killing by splenic and peritoneal lymphocytes in both mouse strains at 5 and 50 mg/kg; however, effects were small in magnitude. | BeP produced minimal effects on cell-mediated immunity in mice. | Wojdani et al. (1984)
In vitro studies
T cell-dependent and polyclonal B-cell antibody responses | Spleen cells from B6C3F1 mice cultured with and without sRBCs were exposed to 0 (polyvinylpyrrolidone vehicle), 0.2, 2, 20, or 200 µg/mL BeP; T cell-dependent antibody response to sRBCs; polyclonal antibody responses to LPS and PPD (B cell); measured on Day 5. | Dose-dependent reduction in response to sRBCs (79 and 100% inhibition at 20 and 200 µg/mL, respectively); reduction in response to LPS (83% decrease) and PPD (46% decrease) at 20 µg/mL. | BeP inhibited both T cell-dependent and polyclonal antibody responses in spleen cells in vitro. | Blanton et al. (1986)
Lymphocyte mitogenesis | Human peripheral blood mononuclear cells were incubated with PHA in the presence of BeP at concentrations of 0 (DMSO vehicle), 0.1, 1, or 10 µM for 72 h; lymphocyte proliferation (i.e., mitogenesis) was measured for each donor (4−8 donors/group). | Lymphocyte mitogenesis was significantly reduced in 1/4 (94% of control), 3/8 (94% of control), and 7/8 (76% control) donors at 0.1, 1, or 10 µM, respectively. | BeP inhibited mitogenesis in human lymphocytes. | Davila et al. (1996)
PTK activation in human T cells | Human HPB-ALL T cells (a leukemia cell line) were exposed to 0 (DMSO vehicle) or 10 µM BeP; total and Fyn- and Zap-70-specific PTK activity were measured in cell lysates after 10 min exposure; total PTK activity was measured in a time course experiment at 5 min, 30 min, and 18 h. | Total PTK activity was increased at 18 h only; total and Fyn- and Zap-70-specific PTK activity were similar to control after 10 min of exposure. | BeP significantly increased total PTK activity in human HPB-ALL T cells after 18 h exposure; the role of increased total PTK activity in BeP immunotoxicity is unclear from the data presented. | Davila et al. (1999)
AHH activity in fresh mitogen activated human lymphocytes | Lymphocytes from a single human donor were suspended in a medium containing pokeweed mitogen and PHA; cells were exposed to 0, 10^−7^, 10^−6^, or 10^−5^ M BeP for 24 h and AHH activity was measured immediately thereafter. | 10^−5^ M BeP inhibited AHH activity in human lymphocytes in vitro (~40% of control, data shown graphically); no effect was observed at lower concentrations (10^−7^ or 10^−6^ M). | The role of AHH inhibition in BeP immunotoxicity is unclear from the data presented. | Gurtoo et al. (1979)
B-cell lymphopoiesis | C57BL/6 murine bone marrow cells were cultured under conditions that favor the growth of pre-B cells; cultures were treated with 0 (acetone vehicle), 10^−7^, 10^−6^, 10^−5^, or 10^−4^ M BeP, and pre-B cells were recovered and counted after 2 and 7 d. | 10^−4^ M BeP decreased the number of pre-B cells after 7 d (~65% of control lymphocytes, data shown graphically); no effect was observed at lower concentrations (10^−7^, 10^−6^, or 10^−5^ M). | BeP inhibited B-cell lymphopoiesis. | Hardin et al. (1992)
Calcium elevation in human T cells | Human HPB-ALL T cells (a leukemia cell line) were exposed to 0 (DMSO vehicle) or 10 µM BeP for 3 min or 4 h; calcium mobilization was determined by a fluo-3 fluorescence flow cytometry assay. | BeP did not induce calcium mobilization in human T cells after 3 min or 4 h. | Calcium elevation was not identified as a mechanism of immunotoxicity in human T cells in this study. | Krieger et al. (1994)
Calcium uptake and activity of calcium ATPases in vesicles prepared from human T cells | ATP-dependent ^45^Ca^2+^ uptake was measured in microsomes prepared from human HPB-ALL T cells after 5 min of incubation with 0 (DMSO vehicle), 0.1, 1, or 10 µM BeP; microsomal Ca^2+^-ATPase activity was measured 30 min following incubation with 10 µM BeP. | Microsomal calcium uptake was inhibited by 19, 25, and 20% of control at 0.1, 1, or 10 µM BeP; no effect was observed on Ca^2+^-ATPase activity. | BeP inhibited calcium uptake in T-cell microsomes; however, the effect was not treatment related. No effect was observed on Ca^2+^-ATPase activity in human T-cell microsomes. | Krieger et al. (1995)
GSH levels in human peripheral blood mononuclear cells (lymphocytes) | Human peripheral blood mononuclear cells obtained from five donors were incubated with 0 (DMSO), 1, or 10 µM for 6, 48, or 72 h. | BeP did not significantly affect GSH in human lymphocytes. | GSH depletion was not identified as a mechanism of immunotoxicity. | Romero et al. (1997)
Differentiation of human monocytes into macrophages | Monocyte cultures prepared from human peripheral blood were exposed to 10 µM BeP for 6 d; formation of adherent macrophages and expression of phenotypic markers (CD71) were monitored. | BeP did not decrease the number of adherent cells or increase the expression of CD71. | BeP did not alter differentiation of human monocytes into macrophages. | van Grevenynghe et al. (2003)
Antibody production by spleen cells in vitro | Spleen cell cultures were prepared from untreated female B6C3F1 mice; cells were incubated with 0 (corn oil vehicle), 0.5, 5, or 50 µg/culture BeP for 4 d; antibody response to sRBCs was measured as AFCs/10^6^ spleen cells (with or without metabolic activation with Arochlor-induced S9). | BeP did not alter the antibody response to sRBCs (with or without metabolic activation). | No effect on humoral immunity in vitro. | White and Holsapple (1984)

AFC = antibody-forming colony(ies); AHH = aryl hydrocarbon hydroxylase; ATP = adenosine triphosphate; BeP = benzo[e]pyrene; Con A = Concanavalin A; DMSO = dimethylsulfoxide; DTH = delayed-type hypersensitivity; GSH = reduced glutathione; IgM = immunoglobin M; i.p. = intraperitoneal; KLH = keyhole limpet hemocyanin; LPS = lipopolysaccharide; PFC = plaque-forming cell; PHA = phytohemagglutinin; PPD = purified protein derivative; PTK = protein tyrosine kinase; s.c. = subcutaneous; sRBC = sheep red blood cell.

#### Effects on Retinal Cells

Several in vitro studies have been performed in retinal cell preparations to evaluate potential PAH-mediated mechanisms for increased risk of age-related macular degeneration in cigarette smokers, because cigarette combustion is a relevant source of exposure to complex PAH mixtures. BaP, the most well-studied PAH, is demonstrated to be metabolized into its diol epoxide by bovine retinal pigment epithelial (RPE) cells, resulting in concomitant DNA-adduct formation and subsequent inhibition of cell growth and replication (Patton et al., 2002). Because the structurally related compound BeP has been characterized at higher concentrations in cigarette smoke than BaP (Patil et al., 2009), several studies were conducted to specifically evaluate the effects of BeP exposure on retinal cell preparations. BeP exposure produced a concentration-dependent reduction in the viability of human retinal pigment epithelial (ARPE-19) cells after 24 hours of treatment (percent viability was 96, 59, 36, and 20% at concentrations of 100, 200, 400, and 1,000 µM, respectively) (Sharma et al., 2008). Apoptosis was induced through the activation of multiple caspase pathways, and inhibition of caspase activation by preincubation with genistein, resveratrol, and memantine was shown to protect the viability of the ARPE-19 cells (Mansoor et al., 2010; Sharma et al., 2008). These data suggest that the decreased viability of human retinal pigment epithelial cells exposed to BeP was due to increased apoptosis mediated through increased caspase signaling.

Pretreatment of ARPE-19 cells with 17β-estradiol was also shown to protect against cytotoxicity of BeP and to reduce markers of apoptosis after BeP exposure. Estrago-Franco et al. (2016) reported that reactive oxygen/reactive nitrogen species (ROS/RNS) and inflammatory cytokines (i.e., IL-6, GM-CSF) were increased in ARPE-19 cells exposed to 200 µM BeP for 24 hours. BeP treatment for 24 hours also reduced cell viability in human microvascular endothelial cells (HMVECs) at concentrations ≥200 µM and in retinal neurosensory (R28) cells at concentrations ≥400 µM (Patil et al., 2009). The mechanism of cytotoxicity differed by cell type and concentration (i.e., no caspase activation in HMVECs; activation of caspases at 100 and 200 µM only in R28 cells) (Patil et al., 2009). Given the multiple modes of genotoxic activity exhibited by PAHs and the complex interplay of DNA damage, metabolic CYP activity, and apoptotic cell death, it is unclear how the cell-specific activity of these molecular pathways will influence cell fate determination described across the different model systems.

In an ex vivo study using porcine retinal arterioles, intraluminal administration of 100 µM BeP for 180 minutes reduced endothelium-dependent, nitric oxide-induced vasodilation via a mechanism involving superoxide production (Kamiya et al., 2017).

#### Cancer

The dermal, lung implantation, and i.p. injection studies that evaluated the carcinogenic potential of BeP in rodents are summarized in Table 4C.

Table 4C Other Route Carcinogenicity Studies of BeP (CASRN 192-97-2)

Test | Materials and Methods | Results (tumor incidence) | References
Dermal complete carcinogenicity study | Female ICR/Ha Swiss mice (100 controls, 50 treated); 0 or 15 μg (0.06 μmol) per application (acetone vehicle); 3 times/wk for 53 wk | [underlined: Skin papillomas]; 0 μmol = 0/100 (0%); 0.06 μmol BeP = 0/50 (0%) | Van Duuren and Goldschmidt (1976)
Dermal complete carcinogenicity study | Female Swiss Millerton (n = 20); 0.1% BeP (acetone vehicle); 3 times/wk for up to 13 mo; no negative control was used; dose (μmol) of BeP could not be calculated because application volume was not reported | A total of 2/20 (10%) mice developed skin papillomas and 3/20 (15%) mice developed skin carcinomas over the course of the study. The first papilloma was observed at 9 mo, when there were only eight survivors, and the first carcinoma at 13 mo, when there were only five survivors. While a negative control was not used, no tumors were induced in 20 mice similarly exposed to 0.1% fluoranthene (9 survivors at 14 mo). In contrast, 19/20 mice similarly treated with 0.01% BaP developed both skin papillomas and carcinomas (first tumors observed at 4 mo; all mice died by 11 mo). The authors characterized their results as showing “very weak” carcinogenic activity for BeP. | Wynder and Hoffmann (1959)
Dermal initiation-promotion study | Female Swiss ICR/HA mice (20/group); single application of 1,000 µg BeP (4 µmol); starting 2 wk later, 25 μg croton resin, 3 times/wk, up to 64 wk; two control groups were used (croton resin only) with no BeP exposure; 25 μg croton resin, 3 times/wk, for 60 or 66 wk; both control groups are presented because neither were exposed for the exact duration as the BeP group | [underlined: Skin papillomas]; 0 µmol (60 wk group) = 1/20 (5%); 0 µmol (66 wk group) = 5/20 (25%); 4 µmol BeP (64 wk) = 2/20 (10%); [underlined: Skin carcinomas]; 0 µmol (60 wk group) = 0/20 (0%); 0 µmol (66 wk group) = 1/20 (5%); 4 µmol BeP (64 wk) = 0/20 (0%) | Van Duuren et al. (1968)
Dermal initiation-promotion study | Female CD-1 mice (30/group); single application of 0 (acetone/DMSO vehicle), single application of 1, 2.5, or 6 μmol BeP; 2.5 or 6 μmol BeP 4,5-dihydrodiol; 1, 2.5, or 6 μmol BeP 9,10-dihydrodiol; 6 μmol BeP H_4_-9,10-diol; or 2.5 μmol 9,10-H_2_ BeP; starting 1 wk later, 16 nmol TPA 2 times/wk for 35 wk | [underlined: Skin papillomas]; 0 (vehicle control) = 7%; 1 μmol BeP = 15%; 2.5 μmol BeP = 11%; 6 μmol BeP = 14%; 2.5 μmol BeP 4,5-dihydrodiol = 14%; 6 μmol BeP 4,5-dihydrodiol = 12%; 1 μmol BeP 9,10-dihydrodiol = 14%; 2.5 μmol BeP 9,10-dihydrodiol = 0%; 6 μmol BeP 9,10-dihydrodiol = 11%; 6 μmol BeP H_4_-9,10-diol = 18%; 2.5 μmol 9,10-H_2_ BeP = 67%^†^; Note: Incidence data reported only as percentages. The study authors indicated that at least 27 mice/group survived to 25 wk. Actual incidences could not be estimated due to unknown animal number/group. | Buening et al. (1980)
Dermal initiation-promotion study | Female CD-1 mice (20/group BeP, 30/group untreated controls); single application of 10 µmol BeP; starting 1 wk later, 5 µmol (exposed) or 10 µmol (untreated controls) TPA 2 times/wk for 35 wk | [underlined: Skin papillomas]; 0 µmol = 0/30 (0%); 10 µmol BeP = 17/20 (85%)^*^ | Scribner (1973)
Dermal initiation-promotion study | Female CD-1 mice (30/group); single application of 0 (TPA only), 100, or 252 µg BeP (0, 0.4, or 1 µmol); starting 1 wk later, 10 µg TPA 2 times/wk for 30 and 40 wk | [underlined: Skin papillomas at 30 wk]:; 0 µmol = 4/30 (14%); 0.4 µmol BeP = 0/30 (0%); 1 µmol BeP = 6/30 (19%); [underlined: Skin carcinomas at 40 wk]:; 0 µmol = 0/30 (0%); 0.4 µmol µg BeP = 0/30 (0%); 1 µmol µg BeP = 0/30 (0%); Note: Incidence data reported only as percentages; actual incidences estimated from number of animals placed on study. | Slaga et al. (1979)
Dermal initiation-promotion study | Female SENCAR mice (30/group); single application of 0 (acetone), 0.4, or 0.8 µmol BeP; starting 2 wk later, 3.4 nmol TPA 2 times/wk for 20 wk | [underlined: Skin papillomas]; 0 µmol = 6/30 (19%); 0.4 µmol BeP = 4/30 (14%); 0.8 µmol BeP = 5/30 (18%); Note: Incidence data reported only as percentages; actual incidences estimated from number of animals placed on study. | Sawyer et al. (1987)
Dermal initiation-promotion study | Female SENCAR mice (30/group); single application of 0 (TPA only) or 2 µmol BeP, BeP 9,10-dihydrodiol, or BeP 9,10-diol-11,12-epoxide; starting 1 wk later, 2 µg TPA 2 times/wk for 15 wk | [underlined: Skin papillomas]; 0 µg = 3/30 (10%); 2 µmol BeP = 5/29 (17%); 2 µmol BeP 9,10-dihydrodiol = 9/28 (32%); 2 µmol BeP 9,10-diol-11,12-epoxide = 2/29 (7%) | Slaga et al. (1980)
Lung implantation study | Female Osborne-Mendel rats (35/group); implantation of 0, 200, 1,000, or 5,000 μg BeP (0, 0.8, 4, or 20 µmol) in a beeswax/trioctanoin pellet; follow-up until moribund or dead | [underlined: Lung carcinomas and sarcomas]; 0 µmol = 0/35 (0%); 0.8 µmol BeP = 0/35 (0%); 4 µmol BeP = 1/30 (3%); 20 µmol BeP = 1/35 (3%) | Deutsch-Wenzel et al. (1983)
i.p. injection study | Experiment 1: Newborn male and female Swiss-Webster BLU:HA (ICR) mice (80/group); total dose of 0 or 2.8 µmol BeP, BeP 4,5-dihydrodiol, or BeP 9,10-dihydrodiol; injections given on PNDs 1, 8, and 15; mice were sacrificed during PNWs 62−66; Experiment 2: Newborn male and female Swiss-Webster BLU:HA (ICR) mice (120/group); total dose of 0 or 5.6 µmol BeP; injections given on PNDs 1, 8, and 15; mice were sacrificed during PNWs 62−66 | Experiment 1:; [underlined: Pulmonary tumors at PNW 62−66 sacrifice]; Females:; 0 µmol = 12/21 (57%); 2.8 µmol BeP = 12/30 (40%); 2.8 µmol BeP 4,5-dihydrodiol = 11/23 (48%); 2.8 µmol BeP 9,10-dihydrodiol = 9/32 (28%); Males:; 0 µmol = 16/38 (42%); 2.8 µmol BeP = 12/30 (41%); 2.8 µmol BeP 4,5-dihydrodiol = 10/18 (56%); 2.8 µmol BeP 9,10-dihydrodiol = 12/28 (43%); [underlined: Hepatic tumors at PNW 62−66 sacrifice]; Females:; 0 µmol = 0/21 (0%); 2.8 µmol BeP = 0/30 (0%); 2.8 µmol BeP 4,5-dihydrodiol = 0/23 (0%); 2.8 µmol BeP 9,10-dihydrodiol = 0/32 (0%); Males:; 0 µmol = 4/38 (11%); 2.8 µmol BeP = 6/30 (21%); 2.8 µmol BeP 4,5-dihydrodiol = 3/18 (17%); 2.8 µmol BeP 9,10-dihydrodiol = 17/28 (61%)^*^; Experiment 2:; [underlined: Pulmonary tumors at PNW 62−66 sacrifice]; Females:; 0 µmol = 12/30 (40%); 5.6 µmol BeP = 6/23 (26%); Males:; 0 µmol = 9/29 (31%); 5.6 µmol BeP = 12/25 (48%); [underlined: Hepatic tumors at PNW 62−66 sacrifice]; Females:; 0 µmol = 0/30 (0%); 5.6 µmol BeP = 0/23 (0%); Males:; 0 µmol = 0/29 (0%); 5.6 µmol BeP = 3/25 (12%) | Buening et al. (1980)
i.p. injection study | Newborn male and female Swiss-Webster BLU:HA (ICR) mice (80 or 100/group); total dose of 0 µmol, 0.07 µmol BeP H_4_-9,10-epoxide or 0.7 µmol BeP, BeP 4,5-oxide, 9,10-H_2_ BeP, BeP diol epoxide (diastereomer 1 and 2); injections given on PNDs 1, 8, and 15; mice were sacrificed during PNWs 39−43 | [underlined: Pulmonary tumors PNW 39−43 sacrifice]; Females:; 0 µmol = 3/24 (13%); 0.07 µmol BeP H_4_-9,10-epoxide = 2/19 (11%); 0.7 µmol BeP = 5/25 (20%); 0.7 µmol BeP 4,5-oxide = 7/30 (23%); 0.7 µmol 9,10-H_2_ BeP = 8/32 (25%); 0.7 µmol BeP diol epoxide 1 = 8/31 (26%); 0.7 µmol BeP diol epoxide 2 = 5/21 (24%); Males:; 0 µmol = 8/37 (22%); 0.07 µmol BeP H_4_-9,10-epoxide = 2/36 (6%); 0.7 µmol BeP = 5/31 (16%); 0.7 µmol BeP 4,5-oxide = 2/37 (5%); 0.7 µmol 9,10-H_2_ BeP = 14/42 (33%); 0.7 µmol BeP diol epoxide 1 = 10/21 (48%); 0.7 µmol BeP diol epoxide 2 = 7/28 (25%); [underlined: Hepatic tumors PNW 39−43 sacrifice]; Females:; 0 µmol = 0/24 (0%); 0.07 µmol BeP H_4_-9,10-epoxide = 0/19 (0%); 0.7 µmol BeP = 0/25 (0%); 0.7 µmol BeP 4,5-oxide = 0/30 (0%); 0.7 µmol 9,10-H_2_ BeP = 0/32 (0%); 0.7 µmol BeP diol epoxide 1 = 0/31 (0%); 0.7 µmol BeP diol epoxide 2 = 0/21 (0%); Males:; 0 µmol = 0/37 (0%); 0.07 µmol BeP H_4_-9,10-epoxide = 1/36 (3%); 0.7 µmol BeP = 2/31 (6%); 0.7 µmol BeP 4,5-oxide = 0/37 (0%); 0.7 µmol 9,10-H_2_ BeP = 2/42 (5%); 0.7 µmol BeP diol epoxide 1 = 1/21 (5%); 0.7 µmol BeP diol epoxide 2 = 6/28 (21%)^*^ | Chang et al. (1981)

† Reported to be “significant” by study authors, although statistics not shown and data reporting inadequate to support independent analysis.

* Statistically significant at p < 0.05 based on two-tailed Fisher’s exact probability test conducted for this review.

9,10-H_2_ BeP = 9,10-dihydrobenzo[e]pyrene; BaP = benzo[a]pyrene; BeP = benzo[e]pyrene; BeP 4,5-dihydrodiol = trans-4,5-dihydroxy-4,5-dihydrobenzo[e]pyrene; BeP 4,5-oxide = benzo[e]pyrene 4,5-oxide; BeP 9,10-dihydrodiol = trans-9,10-dihydroxy-9,10-dihydrobenzo[e]pyrene; BeP 9,10-diol-11,12-epoxide = trans-9,10-dihydroxy-anti-11,12-epoxy-9,10,11,12-tetrahydrobenzo[e]pyrene; BeP diol epoxide 1 = (±)-9β,10α-dihydroxy-11β,12β-epoxy-9,10,11,12-tetrahydrobenzo[e]pyrene; BeP diol epoxide 2 = (±)-9β,10α-dihydroxy-11α,12α-epoxy-9,10,11,12-tetrahydro-benzo[e]pyrene; BeP H_4_-9,10-diol = trans-9,10-dihydroxy-9,10,11,12-tetrahydrobenzo[e]pyrene; BeP H_4_-9,10-epoxide = 9,10-epoxy-9,10,11,12-tetrahydrobenzo[e]pyrene; DMSO = dimethyl sulfoxide; i.p. = intraperitoneal; PND = postnatal day; PNW = postnatal week; TPA = 12-O-tetradecanoylphorbol-13 acetate.

Available skin painting studies do not indicate that BeP is a complete dermal carcinogen. Skin tumors were not observed (0/50) following dermal application of 0.06 μmol BeP in acetone to mice 3 times/week for 53 weeks (Van Duuren and Goldschmidt, 1976). According to the authors of an earlier study (Wynder and Hoffmann, 1959), BeP showed “very weak” carcinogenic activity. In this study, mice treated dermally with an unknown dose of BeP (0.1% in acetone) 3 times/week for up to 13 months developed low incidences of skin papillomas (2/20) and skin carcinomas (3/20 mice). The study was inadequate, however, due to small initial group size (n = 20), high early mortality unrelated to tumor development (only eight survivors at 9 months, when the first tumor was observed), and lack of a negative control group.

The majority of other BeP cancer assays were also negative. BeP was not a skin tumor initiator at single exposure doses up to 6 µmol with 12-O-tetradecanoylphorbol-13 acetate (TPA) as a promoter or up to 4 µmol with croton resin as a promotor (Sawyer et al., 1987; Buening et al., 1980; Slaga et al., 1979; Van Duuren et al., 1968). One study, however, reported significantly increased skin papillomas in mice given BeP as an initiator at 10 µmol with TPA as a promoter (17/20) compared with mice given TPA alone (0/30) (Scribner, 1973). Lung implantation of BeP did not significantly increase the formation of pulmonary tumors in rats (Deutsch-Wenzel et al., 1983). Similarly, i.p. injections of BeP in newborn Swiss Webster mice (on Postnatal Days [PNDs] 1, 8, and 15) at total doses up to 5.6 µmol did not result in an increase in pulmonary or hepatic tumors in adulthood (Chang et al., 1981; Buening et al., 1980).

Similar studies evaluating carcinogenic potential of BeP metabolites were also generally negative. In dermal initiation-promotion studies, only 9,10-dihydrobenzo[e]pyrene was positive, resulting in an increased number of papillomas (67%) compared with vehicle control (7%) following promotion with TPA when tested at 2.5 µmol (Buening et al., 1980). The 9,10-dihydrodiol metabolite resulted in a borderline (p = 0.05) increase in the number of papillomas (9/28) compared with vehicle control (3/30) when tested at 2 µmol using TPA as a promoter (Slaga et al., 1980), but was negative when similarly tested at doses up to 6 µmol in a second study (Buening et al., 1980). Other tested metabolites (n = 3, see Table 4C) were not initiators at doses up to 6 µmol using TPA as a promoter (Buening et al., 1980; Slaga et al., 1980). In injection studies in newborn mice, exposure to the 9,10-dihydrodiol or a diol epoxide on PNDs 1, 8, and 15 (total doses of 2.8 or 0.7 µmol, respectively) resulted in a significant increase in hepatic tumors in adult males, but not hepatic tumors in females or pulmonary tumors in either sex (Chang et al., 1981; Buening et al., 1980). Other tested BeP metabolites (n = 5; see Table 4C) did not induce pulmonary or hepatic tumors following neonatal i.p. injection (Chang et al., 1981; Buening et al., 1980).

Taken together, these data suggest that BeP has low carcinogenic potential. BeP is not a complete dermal carcinogen and did not induce tumors in lung implantation or i.p. studies; however, 1/6 studies reported that BeP was a tumor initiator when administered dermally at high doses. Evidence regarding the carcinogenic potential of BeP metabolites is limited; 1/5 tested metabolites (9,10-dihydrobenzo[e]pyrene) was positive for initiation of skin tumors and 2/7 tested metabolites (a dihydrodiol and a diol epoxide) were positive for induction of tumors following neonatal injection. The relevance of these findings to the oral and inhalation routes of exposure is unclear but do suggest that metabolic processing is required for BeP-mediated carcinogenic activity.

### 2.3.4 Metabolism/Toxicokinetic Studies

No data on absorption or distribution are available for BeP. Because absorption and distribution of a chemical in the body are determined largely by physical and chemical properties related to chemical size and general structure (e.g., lipophilicity, vapor pressure, etc.), it is reasonable to assume that BeP will be absorbed and distributed similarly to other PAHs of similar size and structure with similar physical and chemical properties (e.g., BaP).

Based on data for BaP and other similar PAHs (U.S. EPA, 2017b), BeP is expected to be absorbed through inhalation, oral, and dermal routes of exposure, and generally through diffusion across cell membranes. For inhalation exposure, BeP is expected to adsorb onto particulates in the air and deposit in the respiratory tract with the associated carrier particles. As for other PAHs (IARC, 2010), particle size, region of deposition, and rate of dissolution or desorption from particles are all expected to affect the rate and extent of BeP absorption from the respiratory tract. In general, absorption through airways will likely be biphasic, with rapid absorption occurring through thin epithelia in the alveoli and slower absorption occurring in thicker regions of the airways (ATSDR, 1995). A significant proportion of inhaled BeP is likely to be transported to the gut via the mucociliary escalator (IARC, 2010). For oral exposure, studies with BaP indicate gastrointestinal absorption ranging from 10 to 60% (U.S. EPA, 2017b; ATSDR, 1995). Oral absorption of PAHs in animals is enhanced by the presence of lipophilic compounds, such as oils and fats, and by the presence of bile in the gastrointestinal tract (ATSDR, 1995). Dermal absorption studies with BaP reported rapid and near complete absorption in rats, mice, monkeys, and guinea pigs using vehicles, such as crude oil or acetone, that enhanced absorption (U.S. EPA, 2017b). Dermal absorption was decreased with higher viscosity oil vehicles and in the presence of soils with high organic carbon content (U.S. EPA, 2017b).

Like BaP (U.S. EPA, 2017c; IARC, 2010; ATSDR, 1995), BeP is expected to show widespread, systemic tissue distribution, with initial rapid uptake into highly diffused tissues, such as lung, kidney, liver, and blood, followed by accumulation and retention in fat, with subsequent slow release. Exposure of pregnant rats to BaP both orally and via inhalation indicates that limited placental transfer can occur (U.S. EPA, 2017b; ATSDR, 1995).

PAHs, in general, are metabolized in multiple tissues in the body into more soluble metabolites, including dihydrodiols, phenols, quinones, and epoxides, that form conjugates with glucuronide, glutathione (GSH), or sulfate (U.S. EPA, 2017b; IARC, 2010; ATSDR, 1995). The metabolism of BeP has been investigated in several in vitro studies using hamster or mouse embryo cells, rat liver homogenates, or purified microsomal fractions (Jacob et al., 1985; Jacob et al., 1983; MacLeod et al., 1982; Selkirk et al., 1982; MacLeod et al., 1979; Selkirk and MacLeod, 1979; Wood et al., 1979; Sims, 1970a, b; Duncan et al., 1969). BeP is oxidized via the CYP450 system (Jacob et al., 1985; Jacob et al., 1983; Wood et al., 1979). The primary oxidative metabolites include the k-region 4,5-dihydrodiol and phenolic metabolites, such as 3-hydroxybenzo[e]pyrene (3-OH-BeP) and other phenols with uncertain identities (1-OH, 4-OH, 9-OH, and 10-OH-BeP); BeP quinones have also been identified (Jacob et al., 1985; Jacob et al., 1983; MacLeod et al., 1979; Selkirk and MacLeod, 1979; Sims, 1970a, b). 4,5-Dihydrodiol and the phenols conjugate with uridine diphosphate glucuronic acid to their respective glucuronide conjugates (MacLeod et al., 1982; MacLeod et al., 1979). In contrast to BaP, there is little evidence of direct bay-region activation of BeP, although the characteristic bay region is present within BeP’s structure. The 9,10-dihydrodiol metabolite was detected in trace amounts with rat liver microsomes, generally only after pretreatment with potent monooxygenase inducers, including BaP (Jacob et al., 1985; Jacob et al., 1983; Wood et al., 1979). When the 9,10-dihydrodiol did form, subsequent oxidation was observed to occur at the 4,5-position to form 4,5,9,10-tetrahydroxy-4,5,9,10-tetrahydrobenzyo[e]pyrene, and not the carcinogenic 7,8-diol-9,10-epoxide (Jacob et al., 1985; Jacob et al., 1983). A study with human liver microsomes reported a higher percentage of the 9,10-dihydrodiol metabolite, approximately 12% of the total metabolites, compared with only 1% using liver microsomes from rats pretreated with PAHs (Jacob et al., 1985). Confounding metabolic potential through pretreatment with PAHs is likely to result in decreased rates of individual PAH metabolite production due to the likelihood of other available PAHs acting as a molecular sink for CYP activity. Given the unique and varied metabolic capacity of individual model systems and the discrepancy in production of mutagenic metabolites across those model systems, the significance and contribution of bay region-directed metabolism of BeP remains unclear. Because Jacob et al. (1985) described an increase in production of the proximal carcinogen (9,10-dihydrodiol) in human microsomes compared with that from rodent microsomes, future efforts should be directed at quantifying production of the ultimate diol-epoxide carcinogen within human models systems, as this metabolic step is likely to underlie the moderate carcinogenic potential observed for BeP.

In both mouse and hamster embryo cells, metabolism of BeP was essentially complete by 48 hours (MacLeod et al., 1982; Duncan et al., 1969). In liver microsomes from non-induced rats, the total metabolic rate of BeP was low (2 nmol/mg microsomal protein); metabolic rates of BeP increased significantly in liver microsomes when rats were pretreated with CYP450 inducers (Jacob et al., 1983; Sims, 1970b). Metabolic profiles were similar between rat liver and lung microsomes, and between hepatic microsomes from both rats and mice (Jacob et al., 1985). Metabolism studies with hamster embryo cells indicate the majority (71.7%) of BeP metabolites distribute to extracellular space, while smaller amounts (1.1 and 0.18%) are retained in the cytoplasm and nucleus, respectively (MacLeod et al., 1979).

Based on studies of BaP in multiple species (U.S. EPA, 2017b; IARC, 2010; ATSDR, 1995), excretion, mainly of conjugated metabolites, occurs primarily via biliary excretion to feces, and to a lesser extent, by urine. BaP has also been detected in small amounts in milk (U.S. EPA, 2017b). Excretion half-lives for BaP ranged from 22 to 30 hours in rats following inhalation and dermal exposures, respectively (U.S. EPA, 2017b; ATSDR, 1995).