# 1 INTRODUCTION

Benzo[e]pyrene (BeP), CASRN 192-97-2, belongs to the polycyclic aromatic hydrocarbon (PAH) class of chemicals. PAHs are typically complex mixtures of several PAH compounds that occur naturally in fossil fuels, crude oil, and bituminous coal (NLM, 2019a). BeP is also formed as a product of incomplete combustion of organic matter; it has been found in smoke from tobacco and marijuana cigarettes and in emissions from burning coal, wood, oil, and garbage. BeP has also been detected in both fresh and used motor oils, gasolines, and smoked and cooked food (NLM, 2019a). BeP is purified for use in research laboratories but has no other known uses and is not listed on the U.S. EPA’s Toxic Substances Control Act (TSCA) public inventory (U.S. EPA, 2018b). It is registered with Europe’s Registration, Evaluation, Authorisation and Restriction of Chemicals (REACH) program as a member of the PAH group of chemicals and has a Harmonised Classification Annex VI of Regulation (EC) No. 1272/2008 (CLP Regulation) listing, which requires manufacturers, importers, or downstream users to classify, label, and package BeP before placing it on the market (ECHA, 2019a, b).

The empirical formula for BeP is C_20_H_12_ and its structure is shown in Figure 1. A table of physicochemical properties for BeP is provided in Table 1. BeP is a crystalline solid with negligible water solubility and low vapor pressure. A Henry’s law constant of 1.07 × 10^−6^ atm-m^3^/mol calculated from the extrapolated vapor pressure of 5.7 × 10^−9^ mm Hg and measured water solubility of 1.89 × 10^−8^ mol/L indicates low volatilization of BeP from moist soil and water. No volatilization from dry soil is expected based on the vapor pressure. In the atmosphere, BeP will exist primarily in the particulate phase and to a lesser extent in the vapor phase. The particulate phase BeP in the atmosphere will be removed by wet and dry deposition. BeP absorbs ultraviolet (UV) wavelengths >290 nm; however, removal by direct photodegradation is not expected to be an important pathway based on a measured half-life of 21.1 days in the presence of simulated sunlight (NIST, 2019; Katz, 1979). The rate of photodegradation is expected to increase in the presence of oxidative species, such as oxygen and ozone. The chemical structure of BeP lacks functional groups susceptible to hydrolysis under environmental conditions; therefore, hydrolysis is not expected to be an important degradation route in aqueous environments. BeP is expected to adsorb suspended solids and sediment in water and will be immobile in soil based on a predicted K_oc_ value of 4.66 × 10^5^ in soil. Sorption of PAH compounds, such as BeP, by soil organic matter will limit the potential for biodegradation (WHO, 1998). Limited biodegradation data for BeP indicate slow removal in water and soil under aerobic and anaerobic conditions, with a reported half-life of 875 days in petroleum-contaminated sediment and no removal in an anaerobic sludge digestion study [Kirk and Lesterm (1990) and Callahan et al. (1979) as cited in NLM (2019a)].

Figure 1 Benzo[e]pyrene (CASRN 192-97-2) Structure

This is the beginning of the long description for Figure 1. Figure 1 is titled Benzo e pyrene, C A S Registry Number 1 9 2 dash 9 7 dash 2, Structure. Benzo e pyrene (or B e P) has the empirical formula of C 20 H 12. This is the end of the long description for Figure 1.

Table 1 Physicochemical Properties of BeP (CASRN 192-97-2)^a^

Property (unit) | Value
Physical state | Solid
Boiling point (°C) | 469 (predicted average)
Melting point (°C) | 178
Density (g/cm^3^) | 1.28 (predicted average)
Vapor pressure (mm Hg) | 5.7 × 10^−9^
pH (unitless) | NA
Acid dissociation constant (pKa) (unitless) | NA
Solubility in water (mol/L) | 1.89 × 10^−8^
Octanol-water partition constant (log K_ow_) | 6.44
Henry’s law constant (atm-m^3^/mol) | 1.07 × 10^−6^ (predicted average)
Soil adsorption coefficient (K_oc_) (L/kg) | 4.66 × 10^5^ (predicted average)
Atmospheric OH rate constant (cm^3^/molecule-sec) | 3.45 × 10^−11^ (predicted average)
Atmospheric half-life (d) | 21.10 (measured in simulated sunlight)^b^
Relative vapor density (air = 1) | NV
Molecular weight (g/mol) | 252.316
Flash point (°C) | 230 (predicted average)

a Data were extracted from the U.S. EPA CompTox Chemicals Dashboard: Benzo[e]pyrene, CASRN 192-97-2; https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID3023764#properties; accessed February 8, 2021. Data presented are experimental averages unless otherwise noted.

b Katz (1979).

BeP = benzo[e]pyrene; NA = not applicable; NV = not available.

A summary of available toxicity values for BeP from U.S. EPA and other agencies/organizations is provided in Table 2.

Table 2 Summary of Available Toxicity Values for BeP (CASRN 192-97-2)

Source (parameter)^a,^ ^b^ | Value (applicability) | Notes | Reference^c^
Noncancer
IRIS | NV | NA | U.S. EPA (2020a)
HEAST | NV | NA | U.S. EPA (2011b)
DWSHA | NV | NA | U.S. EPA (2018a)
ATSDR (MRL) | NV | No MRLs were derived for BeP | ATSDR (1995)
IPCS | NV | NA | IPCS (2020)
CalEPA | NV | NA | CalEPA (2019)
OSHA | NV | NA | OSHA (2020); OSHA (2020)
NIOSH | NV | NA | NIOSH (2018)
ACGIH | NV | NA | ACGIH (2020)
Cancer
IRIS | NV | NA | U.S. EPA (2020a)
HEAST | NV | NA | U.S. EPA (2011b)
DWSHA | NV | NA | U.S. EPA (2018a)
NTP | NV | NA | NTP (2016)
IARC (WOE) | Group 3: not classifiable as to its carcinogenicity to humans | Based on inadequate evidence in experimental animals for carcinogenicity | IARC (2010)
CalEPA | NV | NA | CalEPA (2019)
ACGIH | NV | NA | ACGIH (2020)

a Sources: ACGIH = American Conference of Governmental Industrial Hygienists; ATSDR = Agency for Toxic Substances and Disease Registry; CalEPA = California Environmental Protection Agency; DWSHA = Drinking Water Standards and Health Advisories; HEAST = Health Effects Assessment Summary Tables; IARC = International Agency for Research on Cancer; IPCS = International Programme on Chemical Safety; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration.

b Parameters: MRL = minimal risk level; WOE = weight of evidence.

c Reference date is the publication date for the database and not the date the source was accessed.

BeP = benzo[e]pyrene; NA = not applicable; NV = not available.

Literature searches were conducted in August 2019 and updated in August 2021 for studies relevant to the derivation of provisional toxicity values for BeP, CASRN 192-97-2. Searches were conducted using U.S. EPA’s Health and Environmental Research Online (HERO) database of scientific literature. HERO searches the following databases: PubMed, TOXLINE^1^ (including TSCATS1), and Web of Science. The following resources were searched outside of HERO for health-related values: American Conference of Governmental Industrial Hygienists (ACGIH), Agency for Toxic Substances and Disease Registry (ATSDR), California Environmental Protection Agency (CalEPA), Defense Technical Information Center (DTIC), European Centre for Ecotoxicology and Toxicology of Chemicals (ECETOC), European Chemicals Agency (ECHA), U.S. EPA Chemical Data Access Tool (CDAT), U.S. EPA ChemView, U.S. EPA Integrated Risk Information System (IRIS), U.S. EPA Health Effects Assessment Summary Tables (HEAST), U.S. EPA Office of Water (OW), International Agency for Research on Cancer (IARC), U.S. EPA TSCATS2/TSCATS8e, U.S. EPA High Production Volume (HPV), Chemicals via IPCS INCHEM, Japan Existing Chemical Data Base (JECDB), Organisation for Economic Cooperation and Development (OECD) Screening Information Data Sets (SIDS), OECD International Uniform Chemical Information Database (IUCLID), OECD HPV, National Institute for Occupational Safety and Health (NIOSH), National Toxicology Program (NTP), Occupational Safety and Health Administration (OSHA), and World Health Organization (WHO).

1 Note that this version of TOXLINE is no longer updated (https://www.nlm.nih.gov/databases/download/toxlinesubset.html); therefore, it was not included in the literature search update from August 2021.