# APPENDIX D REFERENCES

ACGIH (American Conference of Governmental Industrial Hygienists). (2020). 2020 TLVs and BEIs: Based on the documentation of the threshold limit values for chemical substances and physical agents & biological exposure indices. Cincinnati, OH.
Al-Daghri, NM; Alokail, MS; Abd-Alrahman, SH; Draz, HM. (2014). Polycyclic aromatic hydrocarbon distribution in serum of Saudi children using HPLC-FLD: Marker elevations in children with asthma. Environ Sci Pollut Res Int 21: 12085–12090. 10.1007/s11356-014-3108-0 24923226
Anderson, C; Hehr, A; Robbins, R; Hasan, R; Athar, M; Mukhtar, H; Elmets, CA. (1995). Metabolic requirements for induction of contact hypersensitivity to immunotoxic polyaromatic hydrocarbons. J Immunol 155: 3530–3537.7561049
Andrews, AW; Thibault, LH; Lijinsky, W. (1978). The relationship between carcinogenicity and mutagenicity of some polynuclear hydrocarbons. Mutat Res 51: 311–318. 10.1016/0027-5107(78)90120-3 362176
Archibong, AE; Inyang, F; Ramesh, A; Greenwood, M; Nayyar, T; Kopsombut, P; Hood, DB; Nyanda, AM. (2002). Alteration of pregnancy related hormones and fetal survival in F-344 rats exposed by inhalation to benzo(a)pyrene. Reprod Toxicol 16: 801–808. 10.1016/S0890-6238(02)00058-8 12401509
ATSDR (Agency for Toxic Substances and Disease Registry). (1995). Toxicological profile for polycyclic aromatic hydrocarbons - Update [ATSDR Tox Profile]. (CIS/97/00215). Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. https://www.atsdr.cdc.gov/substances/toxsubstance.asp?toxid=25
ATSDR (Agency for Toxic Substances and Disease Registry). (2005). Toxicological profile for naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene. (PB2006100004). Atlanta, GA. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=PB2006100004
Ball, LM; Warren, SH; Sangaiah, R; Gold, A. (1991). Bacterial mutagenicity of two cyclopentafused isomers of benzpyrene. Mutat Res 271: 271–279. 10.1016/0165-1218(91)90036-L
Blanton, RH; Lyte, M; Myers, MJ; Bick, PH. (1986). Immunomodulation by polyaromatic hydrocarbons in mice and murine cells. Cancer Res 46: 2735–2739.3516385
Brette, F; Shiels, HA; Galli, GL; Cros, C; Incardona, JP; Scholz, NL; Block, BA. (2017). A novel cardiotoxic mechanism for a pervasive global pollutant. Sci Rep 7: 41476. 10.1038/srep41476 28139666
Buening, MK; Levin, W; Wood, AW; Chang, RL; Lehr, RE; Taylor, CW; Yagi, H; Jerina, DM; Conney, AH. (1980). Tumorigenic activity of benzo(e)pyrene derivatives on mouse skin and in newborn mice. Cancer Res 40: 203–206.7356502
CalEPA (California Environmental Protection Agency). (1992). Expedited cancer potency values and proposed regulatory levels for certain Proposition 65 carcinogens. Berkeley, CA: Office of Environmental Health Hazard Assessment, Reproductive and Cancer Hazard Assessment Section. http://www.oehha.ca.gov/prop65/pdf/expcancer.pdf
CalEPA (California Environmental Protection Agency). (2011). Air Toxics Hot Spots program technical support document for cancer potencies. Appendix B. Chemical-specific summaries of the information used to derive unit risk and cancer potency values. Updated 2011. Sacramento, CA: Office of Environmental Health Hazard Assessment. https://oehha.ca.gov/air/crnr/technical-support-document-cancer-potency-factors-2009
CalEPA (California Environmental Protection Agency). (2017). Prop 65: §69502.2(a)(1)(A). Chemicals known to cause cancer and/or reproductive toxicity that are listed under Health and Safety Code section 25249.8 of the California Safe Drinking Water and Toxic Enforcement Act of 1986. Available online
CalEPA (California Environmental Protection Agency). (2019). Consolidated table of OEHHA/ARB approved risk assessment health values (September 19, 2019 ed.). Sacramento, CA: California Air Resources Board. https://www.arb.ca.gov/toxics/healthval/contable.pdf
Casto, BC; Pieczynski, WJ; Janosko, N; Dipaolo, JA. (1976). Significance of treatment interval and DNA repair in the enhancement of viral transformation by chemical carcinogens and mutagens. Chem Biol Interact 13: 105–125.816474
Chang, LH; Young, L. (1943). The metabolism of acenaphthene in the rat. J Biol Chem 151: 87–91.
Chang, RL; Levin, W; Wood, AW; Lehr, RE; Kumar, S; Yagi, H; Jerina, DM; Conney, AH. (1981). Tumorigenicity of the diastereomeric bay-region benzo(e)pyrene 9,10-diol-11,12-epoxides in newborn mice. Cancer Res 41: 915–918.7459878
ChemIDplus. (2021). ChemIDplus advanced. Available online at https://chem.nlm.nih.gov/chemidplus/
Chen, C; Tang, Y; Jiang, X; Qi, Y; Cheng, S; Qiu, C; Peng, B; Tu, B. (2012). Early postnatal benzo(a)pyrene exposure in Sprague-Dawley rats causes persistent neurobehavioral impairments that emerge postnatally and continue into adolescence and adulthood. Toxicol Sci 125: 248–261. 10.1093/toxsci/kfr265 21984485
Cherng, SH; Lin, ST; Lee, H. (1996). Modulatory effects of polycyclic aromatic hydrocarbons on the mutagenicity of 1-nitropyrene: A structure-activity relationship study. Mutat Res Genet Toxicol 367: 177–185. 10.1016/S0165-1218(96)90075-0
Coulomb, H; Gu, Z; Audu, S; Chouroulinkov, I. (1981). The uptake and release of benzo[a]pyrene and benzo[e]pyrene in vitro by Syrian hamster embryo cells as a function of serum concentration. Carcinogenesis 2: 523–527. 10.1093/carcin/2.6.523 6268328
CPDB (Carcinogenic Potency Database). (2011). The carcinogenic potency project: The carcinogenic potency database [Database]: Department of Energy; National Cancer Institute; Environmental Protection Agency; National Institute of Environmental Health Sciences; National Toxicology Program; University of California, Berkeley. Retrieved from https://www.nlm.nih.gov/databases/download/cpdb.html
Curfs, DM; Knaapen, AM; Pachen, DM; Gijbels, MJ; Lutgens, E; Smook, ML; Kockx, MM; Daemen, MJ; van Schooten, FJ. (2005). Polycyclic aromatic hydrocarbons induce an inflammatory atherosclerotic plaque phenotype irrespective of their DNA binding properties. FASEB J 19: 1290–1292. 10.1096/fj.04-2269fje 15939734
Davila, DR; Lane, JL; Lauer, FT; Burchiel, SW. (1999). Protein tyrosine kinase activation by polycyclic aromatic hydrocarbons in human HPB-ALL T cells. J Toxicol Environ Health 56: 249–261. 10.1080/009841099158097
Davila, DR; Romero, DL; Burchiel, SW. (1996). Human T cells are highly sensitive to suppression of mitogenesis by polycyclic aromatic hydrocarbons and this effect is differentially reversed by alpha-naphthoflavone. Toxicol Appl Pharmacol 139: 333–341. 10.1006/taap.1996.0173 8806850
De Flora, S; Zanacchi, P; Camoirano, A; Bennicelli, C; Badolati, GS. (1984). Genotoxic activity and potency of 135 compounds in the Ames reversion test and in a bacterial DNA-repair test [Review]. Mutat Res 133: 161–198. 10.1016/0165-1110(84)90016-2 6374443
Dean, JH; Luster, MI; Boorman, GA; Lauer, LD; Leubke, RW; Lawson, L. (1983). Selective immunosuppression resulting from exposure to the carcinogenic congener of benzopyrene in B6C3F1 mice. Clin Exp Immunol 52: 199–206.6305542
Deutsch-Wenzel, RP; Brune, H; Grimmer, G; Dettbarn, G; Misfeld, J. (1983). Experimental studies in rat lungs on the carcinogenicity and dose-response relationships of eight frequently occurring environmental polycyclic aromatic hydrocarbons. J Natl Cancer Inst 71: 539–544.6577228
DiPaolo, JA; Donovan, P; Nelson, R. (1969). Quantitative studies of in vitro transformation by chemical carcinogens. J Natl Cancer Inst 42: 867–874.4182072
DSSTox (Distributed Structure-Searchable Toxicity). (2018). DSSTox database. Research Triangle Park, NC: U.S. Environmental Protection Agency, National Center for Computational Toxicology. Retrieved from https://www.epa.gov/chemical-research/distributed-structure-searchable-toxicity-dsstox-database
Duncan, M; Brookes, P; Dipple, A. (1969). Metabolism and binding to cellular macromolecules of a series of hydrocarbons by mouse embryo cells in culture. Int J Cancer 4: 813–819. 10.1002/ijc.2910040610 5378608
Dunkel, VC; Zeiger, E; Brusick, D; McCoy, E; McGregor, D; Mortelmans, K; Rosenkranz, HS; Simmon, VF. (1984). Reproducibility of microbial mutagenicity assays: I. Tests with Salmonella typhimurium and Escherichia coli using a standardized protocol. Environ Mutagen 6: 1–251. 10.1002/em.2860060704
Durant, JL; Busby, WF, Jr; Lafleur, AL; Penman, BW; Crespi, CL. (1996). Human cell mutagenicity of oxygenated, nitrated and unsubstituted polycyclic aromatic hydrocarbons associated with urban aerosols. Mutat Res DNA Repair 371: 123–157. 10.1016/S0165-1218(96)90103-2 9008716
ECHA (European Chemicals Agency). (2019a). Substance infocard: Polycyclic-aromatic hydrocarbons (PAH). https://echa.europa.eu/substance-information//substanceinfo/100.239.209
ECHA (European Chemicals Agency). (2019b). Summary of classification and labeling: Benzo(e)pyrene (192-97-2). (601-049-00-6). https://echa.europa.eu/information-on-chemicals/cl-inventory-database/-/discli/details/131125
Estrago-Franco, MF; Moustafa, MT; Riazi-Esfahani, M; Sapkal, AU; Piche-Lopez, R; Patil, AJ; Sharma, A; Falatoonzadeh, P; Chwa, M; Luczy-Bachman, G; Kuppermann, BD; Kenney, MC. (2016). Effects of benzo(e)pyrene on reactive oxygen/nitrogen species and inflammatory cytokines induction in human RPE cells and attenuation by mitochondrial-involved mechanism. Journal of Ophthalmic & Vision Research 11: 385–393. 10.4103/2008-322X.194091 27994808
Fujikawa, K; Fort, FL; Samejima, K; Sakamoto, Y. (1993). Genotoxic potency in Drosophila melanogaster of selected aromatic amines and polycyclic aromatic hydrocarbons as assayed in the DNA repair test. Mutat Res 290: 175–182. 10.1016/0027-5107(93)90157-B 7694108
Grantham, PH. (1963). Metabolism of fluorene-9-C14 in rats, guinea pigs, and rabbits. Biochemistry 2: 610–616. 10.1021/bi00903a038 14069556
Gupta, P; Banerjee, DK; Bhargava, SK; Kaul, R; Shanker, VR. (1994). Abnormal pattern of lung functions in rubber factory workers. J Indian Med Assoc 92: 260–263.7963614
Gupta, P; Makhijani, SD; Meenakshi, C. (1998). Pulmonary function tests on rubber factory workers exposed to polynuclear aromatic hydrocarbons. Indian J Physiol Allied Sci 52: 71–75.
Gurtoo, HL; Parker, NB; Paigen, B; Havens, MB; Minowada, J; Freedman, HJ. (1979). Induction, inhibition and some enzymological properties of aryl hydrocarbon hydroxylase in fresh mitogen-activated human lymphocytes. Cancer Res 39: 4620–4629.498091
Haas, BS; Brooks, EE; Schumann, KE; Dornfeld, SS. (1981). Synergistic, additive and antagonistic mutagenic responses to binary mixtures of benzo(a)pyrene and benzo(e)pyrene as detected by strains TA98 and TA100 in the Salmonella microsome assay. Environ Mutagen 3: 159–166. 10.1002/em.2860030207 6263605
Hardin, JA; Hinoshita, F; Sherr, DH. (1992). Mechanisms by which benzo[a]pyrene, an environmental carcinogen, suppresses B cell lymphopoiesis. Toxicol Appl Pharmacol 117: 155–164.1335172
Huberman, E. (1977). Viral antigen induction and mutability of different genetic loci by metabolically activated carcinogenic polycyclic hydrocarbons in cultured mammalian cells. In Cold Spring Harbor conferences on cell proliferation (pp. 1521–1535). (EMICBACK/28591). Cold Spring Harbor Laboratory: Cold Spring Harbor, NY.
IARC (International Agency for Research on Cancer). (1983). IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans: Polynuclear aromatic compounds, Part I. Chemical, environmental and experimental data [IARC Monograph]. Lyon, France: World Health Organization, International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Monographs/vol1-42/mono32.pdf
IARC (International Agency for Research on Cancer). (2010). Some non-heterocyclic polycyclic aromatic hydrocarbons and some related exposures. IARC monographs on the evaluation of carcinogenic risks to humans [IARC Monograph] (pp. 1–853). Lyon, France. http://monographs.iarc.fr/ENG/Monographs/vol92/mono92.pdf
IARC (International Agency for Research on Cancer). (2018). IARC monographs on the evaluation of carcinogenic risk to humans. http://monographs.iarc.fr/ENG/Monographs/PDFs/index.php
IPCS (International Programme on Chemical Safety). (2020). INCHEM: Chemical safety information from intergovernmental organizations [Database]. Geneva, Switzerland: World Health Organization, Canadian Centre for Occupational Health and Safety. Inter-Organization Programme for the Sound Management of Chemicals. Retrieved from http://www.inchem.org/
Jacob, J; Schmoldt, A; Grimmer, G. (1983). Benzo(e)pyrene metabolism in rat liver microsomes: Dependence of the metabolite profile on the pretreatment of rats with various monooxygenase inducers. Carcinogenesis 4: 905–910. 10.1093/carcin/4.7.905 6872145
Jacob, J; Schmoldt, A; Grimmer, G; Hamann, M; Raab, G. (1985). Benzo(e)pyrene metabolism: Identification and quantitative analysis of metabolites formed by liver microsomes of variously pretreated rats by means of capillary gas chromatography/mass spectrometry. In J Cooke; AJ Dennis (Eds.), Polynuclear aromatic hydrocarbons: Mechanisms, methods and metabolism (pp. 627–641). Columbus, OH: Battelle Memorial Institute.
Kaden, DA; Hites, RA; Thilly, WG. (1979). Mutagenicity of soot and associated polycyclic aromatic hydrocarbons to Salmonella typhimurium. Cancer Res 39: 4152–4159.383281
Kamiya, T; Nagaoka, T; Omae, T; Ono, S; Otani, S; Yoshida, A. (2017). Benzo(e)pyrene inhibits endothelium-dependent no-mediated dilation of retinal arterioles via superoxide production and endoplasmic reticulum stress. Invest Ophthalmol Vis Sci 58: 5978–5984. 10.1167/iovs.17-21925 29183043
Katz, M. (1979). Analysis of polycyclic aromatic hydrocarbons in atmospheric suspended particulate matter. In H Egan; M Castegnaro; H Kunte; P Bogovski; EA Walker (Eds.), Environmental carcinogens: Selected methods of analysis Analysis of polycyclic aromatic hydrocarbons in environmental samples. Lyon, France: International Agency For Research On Cancer. http://publications.iarc.fr/Book-And-Report-Series/Iarc-Scientific-Publications/Environmental-Carcinogens-Selected-Methods-Of-Analysis-Volume-3-Analysis-Of-Polycyclic-Aromatic-Hydrocarbons-In-Environmental-Samples-1979
Kirkland, D; Aardema, M; Henderson, L; Müller, L. (2005). Evaluation of the ability of a battery of three in vitro genotoxicity tests to discriminate rodent carcinogens and non-carcinogens: I. Sensitivity, specificity and relative predictivity. Mutat Res 584: 1–256. 10.1016/j.mrgentox.2005.02.004 15979392
Kitchin, KT; Brown, JL; Kulkarn, AP. (1992). Predictive assay for rodent carcinogenicity using in vivo biochemical parameters: Operational characteristics and complementarity. Mutat Res 266: 253–272. 10.1016/0027-5107(92)90193-6 1373835
Kitchin, KT; Brown, JL; Kulkarni, AP. (1993). Predicting rodent carcinogenicity of Ames test false positives by in vivo biochemical parameters. Mutat Res 290: 155–164. 10.1016/0027-5107(93)90155-9 7694106
Krieger, JA; Born, JL; Burchiel, SW. (1994). Persistence of calcium elevation in the HPB-all human T-cell line correlates with immunosuppressive properties of polycyclic aromatic hydrocarbons. Toxicol Appl Pharmacol 127: 268–274. 10.1006/taap.1994.1161 8048070
Krieger, JA; Davila, DR; Lytton, J; Born, JL; Burchiel, SW. (1995). Inhibition of sarcoplasmic/endoplasmic reticulum calcium ATPases (SERCA) by polycyclic aromatic hydrocarbons in HPB-ALL human T cells and other tissues. Toxicol Appl Pharmacol 133: 102–108. 10.1006/taap.1995.1131 7597699
Lavoie, EJ; Bedenko, EV; Hirota, N; Hecht, SS; Hoffmann, D. (1979). A comparison of the mutagenicity, tumor-initiating activity and complete carcinogenicity of polynuclear aromatic hydrocarbons. In PW Jones; P Leber (Eds.), Polynuclear aromatic hydrocarbons (pp. 705–721). Ann Arbor, MI: Ann Arbor Science Publishers, Inc.
Lipniak, M; Brandys, J. (1993). Toxicokinetics of fluoranthene, pyrene and benz(a)anthracene in the rat. Polycycl Aromat Compd 3: 111–119. 10.1080/10406639308047863
Ma, X; Gibbons, JA; Babish, JG. (1991). Benzo(e)pyrene pretreatment of immature, female C57BL/6J mice results in increased bioactivation of aflatoxin B1 in vitro. Toxicol Lett 59: 51–58. 10.1016/0378-4274(91)90054-A 1755035
MacLeod, MC; Cohen, GM; Selkirk, JK. (1979). Metabolism and macromolecular binding of the carcinogen benzo[a]pyrene and its relatively inert isomer benzo[e]pyrene by hamster embryo cells. Cancer Res 39: 3463–3470.476676
MacLeod, MC; Mansfield, BK; Selkirk, JK. (1982). Time course of metabolism of benzo(e)pyrene by hamster embryo cells and the effect of chemical modifiers. Chem Biol Interact 40: 275–285. 10.1016/0009-2797(82)90151-X 6282473
Mane, SS; Purnell, DM; Hsu, IC. (1990). Genotoxic effects of five polycyclic aromatic hydrocarbons in human and rat mammary epithelial cells. Environ Mol Mutagen 15: 78–82.2307152
Mansoor, S; Gupta, N; Patil, AJ; Estrago-Franco, MF; Ramirez, C; Migon, R; Sapkal, A; Kuppermann, BD; Kenney, MC. (2010). Inhibition of apoptosis in human retinal pigment epithelial cells treated with benzo(e)pyrene, a toxic component of cigarette smoke. Invest Ophthalmol Vis Sci 51: 2601–2607. 10.1167/iovs.09-4121 19959636
McCann, J; Choi, E; Yamasaki, E; Ames, BN. (1975). Detection of carcinogens as mutagens in the Salmonella/microsome test: Assay of 300 chemicals. Proc Natl Acad Sci USA 72: 5135–5139. 10.1073/pnas.72.12.5135 1061098
Mersch-Sundermann, V; Mochayedi, S; Kevekordes, S. (1992). Genotoxicity of polycyclic aromatic hydrocarbons in Escherichia coli PQ37. Mutat Res 278: 1–9. 10.1016/0165-1218(92)90279-9 1370113
Mersch-Sundermann, V; Mochayedi, S; Kevekordes, S; Kern, S; Wintermann, F. (1993). The genotoxicity of unsubstituted and nitrated polycyclic aromatic hydrocarbons. Anticancer Res 13: 2037–2043.8297112
Milo, GE; Blakeslee, J; Yohn, DS; Dipaolo, JA. (1978). Biochemical activation of aryl hydrocarbon hydroxylase activity, cellular distribution of polynuclear hydrocarbon metabolites, and DNA damage by polynuclear hydrocarbon products in human cells in vitro. Cancer Res 38: 1638–1644.417805
Motykiewicz, G; Michalska, J; Pendzich, J; Małusecka, E; Strózyk, M; Kalinowska, E; Butkiewicz, D; Mielzyńska, D; Midro, A; Santella, RM; Chorazy, M. (1998). A molecular epidemiology study in women from Upper Silesia, Poland. Toxicol Lett 96–97: 195–202. 10.1016/S0378-4274(98)00072-1
Munson, AE; White, KL. (1983). Fourth interim report on effect of subchronic fourteen day exposure to benzopyrene in B6C3F1 male and female mice on specific immunological parameters with cover letter [TSCA Submission]. (#FYI-AX-0382-0220. TSCATS/031213). Washington, DC: Medical College of Virginia, American Petroleum Institute.
Munson, AE; White, KL. (1986). Immunotoxicology of benzopyrenes in Fisher 344 rats (final report) with cover letter dated 05-19-1986 [TSCA Submission]. (OTS00003093. #FYI-AX-0686-0309. TSCATS/200128). Washington, DC: Medical College of Virginia, American Petroleum Institute.
Munson, AE; White, KL. (1992). Effects of subchronic 14-day exposure to benzopyrene in B6C3F1 male and female mice on specific immunological parameters [TSCA Submission]. (OTS0000901K4. #FYI-0892-0901. TSCATS/452123). Medical College of Virginia, American Petroleum Institute.
Munson, AE; White, KL; Lysy, HH. (1985). Effects of subchronic fourteen day exposure to benzopyrene in B6C3F1 female mice on host resistance with cover letter 041585 [TSCA Submission]. (OTS00002202. #FYI-AX-0485-0220. TSCATS/035026). Washington, DC: Medical College of Virginia, American Petroleum Institute.
Neish, WJ. (1948). Metabolism of fluorene in the rabbit. Biochem J 43: 533–537. 10.1042/bj0430533 16748447
NIOSH (National Institute for Occupational Safety and Health). (1986). Health hazard evaluation report No. HETA-84-284-1701, Granite City Steel, Granite City, Illinois (pp. 84–284). (NIOSH/00163543).
NIOSH (National Institute for Occupational Safety and Health). (1987). Health hazard evaluation report No. HETA-84-284-1701B, revised, Granite City Steel, Granite City, Illinois. (HETA-84-284-1701B). Cincinnati, OH: U.S. Department of Health and Human Services. http://www.cdc.gov/niosh/nioshtic-2/00173104.html
NIOSH (National Institute for Occupational Safety and Health). (2018). NIOSH pocket guide to chemical hazards. Index of chemical abstracts service registry numbers (CAS No.). Atlanta, GA. http://www.cdc.gov/niosh/npg/npgdcas.html
NIST (National Institute of Standards and Technology). (2019). NIST chemistry webbook. Benzo[e]pyrene (192-97-2). Standard reference database No. 69. https://webbook.nist.gov/cgi/cbook.cgi?ID=192-97-2&Units=SI
NLM (National Library of Medicine). (2019a). HSDB annotation record: Benzo[e]pyrene. Bethesda, MD: National Center for Biotechnology Information. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/4031
NLM (National Library of Medicine). (2019b). Pubchem compounds summary: Acenaphthene, 83-32-9. Available online at https://pubchem.ncbi.nlm.nih.gov/compound/Acenaphthene
NLM (National Library of Medicine). (2019c). Pubchem compounds summary: Anthracene, 120-12-7. Available online at https://pubchem.ncbi.nlm.nih.gov/compound/8418
NLM (National Library of Medicine). (2019d). Pubchem compounds summary: Benzo[a]pyrene, 50-32-8. Available online at https://pubchem.ncbi.nlm.nih.gov/compound/2336
NLM (National Library of Medicine). (2019e). Pubchem compounds summary: Benzo[e]pyrene, 192-97-2. Available online at https://pubchem.ncbi.nlm.nih.gov/compound/9128
NLM (National Library of Medicine). (2019f). Pubchem compounds summary: Fluoranthene, 206-44-0. Available online at https://pubchem.ncbi.nlm.nih.gov/compound/9154
NLM (National Library of Medicine). (2019g). Pubchem compounds summary: Fluorene, 86-73-7. Available online at https://pubchem.ncbi.nlm.nih.gov/compound/6853
NLM (National Library of Medicine). (2019h). Pubchem compounds summary: Pyrene, 129-00-0. Available online at https://pubchem.ncbi.nlm.nih.gov/compound/31423
Novicki, DL; Rosenberg, MR; Michalopoulos, G. (1985). Inhibition of DNA synthesis by chemical carcinogens in cultures of initiated and normal proliferating rat hepatocytes. Cancer Res 45: 337–344.3965143
NTP (National Toxicology Program). (2016). 14th Report on carcinogens. Research Triangle Park, NC. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html
NTP (National Toxicology Program). (2017). NTP technical reports index. Available online at https://ntp.niehs.nih.gov/results/summaries/chronicstudies/index.html
OECD (Organisation for Economic Co-operation and Development). (2019). The OECD QSAR toolbox [version 4.3.1]. Retrieved from http://www.oecd.org/chemicalsafety/risk-assessment/oecd-qsar-toolbox.htm
OSHA (Occupational Safety & Health Administration). (2020). Air contaminants: Occupational safety and health standards for shipyard employment, subpart Z, toxic and hazardous substances. (OSHA Standard 1915.1000). Washington, DC. https://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10286
Patil, AJ; Sharma, A; Seigel, GM; Gramajo, A; Chwa, M; Kuppermann, BD; Kenney, MC. (2009). Effects of benzo(e)pyrene on the retinal neurosensory cells and human microvascular endothelial cells in vitro. Curr Eye Res 34: 672–682. 10.1080/02713680903015892 19899995
Patton, WP; Routledge, MN; Jones, GD; Lewis, SE; Archer, DB; Davies, RJ; Chakravarthy, U. (2002). Retinal pigment epithelial cell DNA is damaged by exposure to benzo[a]pyrene, a constituent of cigarette smoke. Exp Eye Res 74: 513–522. 10.1006/exer.2001.1160 12076095
Penn, A; Snyder, C. (1988). Arteriosclerotic plaque development is ‘promoted’ by polynuclear aromatic hydrocarbons. Carcinogenesis 9: 2185–2189. 10.1093/carcin/9.12.2185 3142695
Platt, KL; Aderhold, S; Kulpe, K; Fickler, M. (2008). Unexpected DNA damage caused by polycyclic aromatic hydrocarbons under standard laboratory conditions. Mutat Res 650: 96–103. 10.1016/j.mrgentox.2007.09.011 18160334
Platt, KL; Petrovic, P; Seidel, A; Beermann, D; Oesch, F. (1988). Microsomal metabolism of picene. Chem Biol Interact 66: 157–175. 10.1016/0009-2797(88)90069-5 3396119
Probst, GS; Mcmahon, RE; Hill, LE; Thompson, CZ; Epp, JK; Neal, SB. (1981). Chemically-induced unscheduled DNA synthesis in primary rat hepatocyte cultures: A comparison with bacterial mutagenicity using 218 compounds. Environ Mutagen 3: 11–32. 10.1002/em.2860030103 7021142
Prodi, G; Rocchi, P; Grilli, S. (1975). The effect of polycyclic hydrocarbons on the synthesis of DNA on lymphoid organs bone marrow and regenerating rat liver. Experientia 31: 358–360.1116551
Reddy, MV; Gupta, RC; Randerath, E; Randerath, K. (1984). 32 P-postlabeling test for covalent DNA binding of chemicals in vivo: Application to a variety of aromatic carcinogens and methylating agents. Carcinogenesis 5: 231–244. 10.1093/carcin/5.2.231 6697441
Rees, ED; Majumdar, SK; Shuck, A. (1970). Changes in chromosomes of bone marrow after intravenous injections of 7,12-dimethylbenz(a)anthracene and related compounds. Proc Natl Acad Sci USA 66: 1228–1235. 10.1073/pnas.66.4.1228 5273451
Revis, NW; Bull, R; Laurie, D; Schiller, CA. (1984). The effectiveness of chemical carcinogens to induce atherosclerosis in the white Carneau pigeon. Toxicology 32: 215–227. 10.1016/0300-483X(84)90075-1 6089378
Romero, DL; Mounho, BJ; Lauer, FT; Born, JL; Burchiel, SW. (1997). Depletion of glutathione by benzo(a)pyrene metabolites, ionomycin, thapsigargin, and phorbol myristate in human peripheral blood mononuclear cells. Toxicol Appl Pharmacol 144: 62–69. 10.1006/taap.1997.8113 9169070
Roszinsky-Köcher, G; Basler, A; Roehrborn, G. (1979). Mutagenicity of polycyclic hydrocarbons. V. Induction of sister-chromatid exchanges in vivo. DNA Repair 66: 65–67. 10.1016/0165-1218(79)90008-9
Sakai, M; Yoshida, D; Mizusaki, S. (1985). Mutagenicity of polycyclic aromatic hydrocarbons and quinones on Salmonella typhimurium TA97. Mutat Res 156: 61–67. 10.1016/0165-1218(85)90007-2 3889628
Salamone, MF; Heddle, JA; Katz, M. (1979). The mutagenic activity of thirty polycyclic aromatic hydrocarbons (PAH) and oxides in urban airborne particulates. Environ Int 2: 37–43. 10.1016/0160-4120(79)90092-8
Sato, S; Kitajima, H; Konishi, S; Takizawa, H; Inui, N. (1987). Mouse strain differences in the induction of micronuclei by polycyclic aromatic hydrocarbons. Mutat Res 192: 185–189. 10.1016/0165-7992(87)90054-6 3120001
Sawyer, TW; Chang, K; Harvey, RG; Digiovanni, J. (1987). Further investigations into the effect of non-benzo ring bay-region methyl substituents on tumor-initiating activity of polycyclic hydrocarbons. Cancer Lett 36: 317–324. 10.1016/0304-3835(87)90025-5 3115560
Schiff, LJ; Elliott, SF; Moore, SJ; Urcan, MS; Graham, JA. (1983). Unscheduled DNA synthesis in hamster tracheal epithelium exposed in vitro to chemical carcinogens and environmental pollutants. In MD Waters (Ed.), Short-term bioassays in the analysis of complex environmental mixtures III (pp. 277–284). New York, NY: Springer. http://link.springer.com/chapter/10.1007%2F978-1-4613-3611-2_19
Schmitt, M; Kempf, C; Kempf, J. (1984). Endogenous activation by indirect muta-carcinogens and DNA-repair synthesis in mouse-lung fibroblast cultures. Mutat Res 132: 197–201.6513972
Scribner, JD. (1973). Tumor initiation by apparently noncarcinogenic polycyclic aromatic hydrocarbons. J Natl Cancer Inst 50: 1717–1719. 10.1093/jnci/50.6.1717 4123924
Segerbäck, D; Vodicka, P. (1993). Recoveries of DNA adducts of polycyclic aromatic hydrocarbons in the 32P-postlabelling assay. Carcinogenesis 14: 2463–2469. 10.1093/carcin/14.12.2463 8269613
Selkirk, JK; MacLeod, MC. (1979). Metabolism and macromolecular binding of benzo(a)pyrene and its noncarcinogenic isomer benzo(e)pyrene in cell culture. In PW Jones; P Leber (Eds.), Polynuclear aromatic hydrocarbons: 3rd international symposium on chemistry and biology - carcinogenesis and mutagenesis, Columbus, Oct 1978, proceedings (pp. 21–35). Ann Arbor, Michigan: AASP.
Selkirk, JK; MacLeod, MC; Mansfield, BK; Nikbakht, A. (1982). Metabolic rationale for the weak mutagenic and carcinogenic activity of benzo(e)pyrene. In T Sugimura; S Kondo; H Takebe (Eds.), Environmental mutagens and carcinogens: Proceedings of the 3rd international conference. New York, NY: Alan R. Liss.
Serdar, B; Brindley, S; Dooley, G; Volckens, J; Juarez-Colunga, E; Gan, R. (2016). Short-term markers of DNA damage among roofers who work with hot asphalt. Environ Health 15: 99. 10.1186/s12940-016-0182-4 27765036
Sharma, A; Neekhra, A; Gramajo, AL; Patil, J; Chwa, M; Kuppermann, BD; Kenney, MC. (2008). Effects of benzo(e)pyrene, a toxic component of cigarette smoke, on human retinal pigment epithelial cells in vitro. Invest Ophthalmol Vis Sci 49: 5111–5117. 10.1167/iovs.08-2060 18586875
Simmon, VF. (1979). In vitro mutagenicity assays of chemical carcinogens and related compounds with Salmonella typhimurium. J Natl Cancer Inst 62: 893–899.372657
Sims, P. (1964). Metabolism of polycyclic compounds. 25. The metabolism of anthracene and some related compounds in rats. Biochem J 92: 621–631. 10.1042/bj0920621 5837444
Sims, P. (1970a). The metabolism of some aromatic hydrocarbons by mouse embryo cell cultures. Biochem Pharmacol 19: 285–297. 10.1016/0006-2952(70)90348-5 5507643
Sims, P. (1970b). Qualitative and quantitative studies on the metabolism of a series of aromatic hydrocarbons by rat-liver preparations. Biochem Pharmacol 19: 795–818. 10.1016/0006-2952(70)90243-1 5507686
Slaga, TJ; Gleason, GL; Mills, G; Ewald, L; Fu, PP; Lee, HM; Harvey, RG. (1980). Comparison of the skin tumor-initiating activities of dihydrodiols and diol-epoxides of various polycyclic aromatic hydrocarbons. Cancer Res 40: 1981–1984.7371034
Slaga, TJ; Jecker, L; Bracken, WM; Weeks, CE. (1979). The effects of weak or non-carcinogenic polycyclic hydrocarbons on 7,12-dimethylbenz[a]anthracene and benzo[a]pyrene skin tumor-initiation. Cancer Lett 7: 51–59. 10.1016/S0304-3835(79)80076-2 110441
Teranishi, K; Hamada, K; Watanabe, H. (1975). Quantitative relationship between carcinogenicity and mutagenicity of polyaromatic hydrocarbons in Salmonella typhimurium mutants. DNA Repair 31: 97–102.
Tokiwa, H; Nakanishi, Y; Sera, N; Hara, N; Inuzuka, S. (1998). Analysis of environmental carcinogens associated with the incidence of lung cancer. Toxicol Lett 99: 33–41. 10.1016/S0378-4274(98)00136-2 9801028
Toma, I; McCaffrey, TA. (2012). Transforming growth factor-beta and atherosclerosis: interwoven atherogenic and atheroprotective aspects. Cell Tissue Res 347: 155–175. 10.1007/s00441-011-1189-3 21626289
U.S. EPA (U.S. Environmental Protection Agency). (1986). Guidelines for carcinogen risk assessment [EPA Report] (pp. 33993–34003). (EPA/630/R-00/004). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/iris/basic-information-about-integrated-risk-information-system#risk
U.S. EPA (U.S. Environmental Protection Agency). (1990a). Integrated Risk Information System (IRIS) chemical assessment summary for acenaphthene (CASRN 83-32-9). Washington, DC: National Center for Environmental Assessment, Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0442_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1990b). Integrated Risk Information System (IRIS) chemical assessment summary for anthracene (CASRN 120-12-7). Washington, DC: National Center for Environmental Assessment, Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0434_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1990c). Integrated Risk Information System (IRIS) chemical assessment summary for dibenz[a,h]anthracene (CASRN 53-70-3). Washington, DC: National Center for Environmental Assessment, Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0456_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1990d). Integrated Risk Information System (IRIS) chemical assessment summary for fluoranthene (CASRN 206-44-0). Washington, DC: National Center for Environmental Assessment, Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0444_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1990e). Integrated Risk Information System (IRIS) chemical assessment summary for fluorene (CASRN 86-73-7). Washington, DC: National Center for Environmental Assessment, Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0435_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1990f). Integrated Risk Information System (IRIS) chemical assessment summary for pyrene (CASRN 129-00-0). Washington, DC: National Center for Environmental Assessment, Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0445_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1991). Guidelines for developmental toxicity risk assessment. Fed Reg 56: 63798–63826.
U.S. EPA (U.S. Environmental Protection Agency). (1993). Integrated Risk Information System (IRIS) chemical assessment summary for 1,2-dichloroethane (CASRN 107-06-2). https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0149_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2005). Guidelines for carcinogen risk assessment [EPA Report]. (EPA/630/P-03/001F). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3-25-05.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2007). Provisional peer-reviewed toxicity values for perylene (CASRN 198-55-0) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Perylene.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009). Provisional peer-reviewed toxicity values for anthracene (CASRN 120-12-7) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Anthracene.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2011a). Chemical Assessment Clustering Engine (ChemACE) [Database]. Retrieved from https://www.epa.gov/tsca-screening-tools/chemical-assessment-clustering-engine-chemace
U.S. EPA (U.S. Environmental Protection Agency). (2011b). Health effects assessment summary tables (HEAST) for superfund. Available online at https://epa-heast.ornl.gov/heast.php
U.S. EPA (U.S. Environmental Protection Agency). (2011c). Provisional peer-reviewed toxicity values for acenaphthene (CASRN 83-32-9) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Acenaphthene.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2012). Provisional peer-reviewed toxicity values for fluoranthene (CASRN 206-44-0) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Fluoranthene.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2017a). IRIS carcinogens: §69502.2(a)(1)(E). Chemicals that are identified as “carcinogenic to humans,” “likely to be carcinogenic to humans,” or Group A, B1, or B2 carcinogens in the United States Environmental Protection Agency’s Integrated Risk Information System. Available online
U.S. EPA (U.S. Environmental Protection Agency). (2017b). Toxicological review of benzo[a]pyrene (CASRN 50-32-8): Supplemental information [EPA Report]. (EPA/635/R-17/003Fb). Washington, DC: U.S. Environmental Protection Agency, Integrated Risk Information System. https://cfpub.epa.gov/si/si_public_file_download.cfm?p_download_id=535926&Lab=NCEA
U.S. EPA (U.S. Environmental Protection Agency). (2017c). Toxicological review of benzo[a]pyrene [CASRN 50-32-8] [EPA Report]. (EPA/635/R-17/003Fa). Washington, DC: U.S. Environmental Protection Agency, Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0136tr.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2018a). 2018 Edition of the drinking water standards and health advisories [EPA Report]. (EPA/822/F-18/001). Washington, DC: U.S. Environmental Protection Agency, Office of Water. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2018b). How to access the TSCA inventory. Download the non-confidential TSCA inventory [Database]. Retrieved from http://www2.epa.gov/tsca-inventory/how-access-tsca-inventory
U.S. EPA (U.S. Environmental Protection Agency). (2020a). Integrated risk information system. IRIS assessments [Database]. Washington, DC. Retrieved from http://www.epa.gov/iris/
U.S. EPA (U.S. Environmental Protection Agency). (2020b). Provisional peer-reviewed toxicity values (PPRTVs) for superfund: Derivation support documents [Database]. Washington, DC. Retrieved from https://www.epa.gov/pprtv
Van Duuren, BL; Goldschmidt, BM. (1976). Cocarcinogenic and tumor-promoting agents in tobacco carcinogenesis. J Natl Cancer Inst 56: 1237–1242.994224
Van Duuren, BL; Sivak, A; Langseth, L; Goldschmidt, BM; Segal, A. (1968). Initiators and promoters in tobacco carcinogenesis. Natl Canc Inst Monogr 28: 173–180.
van Grevenynghe, J; Rion, S; Le Ferrec, E; Le Vee, M; Amiot, L; Fauchet, R; Fardel, O. (2003). Polycyclic aromatic hydrocarbons inhibit differentiation of human monocytes into macrophages. J Immunol 170: 2374–2381. 10.4049/jimmunol.170.5.2374 12594260
Vandervort, R; Lucas, JB. (1974). Health hazard evaluation determination report No. HHE-72-77-109, Ashland Oil Incorporated, Catlettsburg, Kentucky (pp. 72–77). (NIOSH-TR-109-74). Rockville, MD: National Institute for Occupational Safety and Health (NIOSH).
Ved Brat, S; Tong, C; Telang, S; Williams, GM. (1983). Comparison of sister chromatid exchange and mammalian cell mutagenesis at the hypoxanthine guanine phosphoribosyl transferase locus in adult rat liver epithelial cells [Abstract]. Ann N Y Acad Sci 407: 474–475. 10.1111/j.1749-6632.1983.tb47868.x
Vienneau, DS; Deboni, U; Wells, PG. (1995). Potential genoprotective role for UDP-glucuronosyltransferases in chemical carcinogenesis: Initiation of micronuclei by benzo(a)pyrene and benzo(e)pyrene in UDP-glucuronosyltransferase-deficient cultured rat skin fibroblasts. Cancer Res 55: 1045–1051.7866987
Walker, SA; Addai, AB; Mathis, M; Ramesh, A. (2007). Effect of dietary fat on metabolism and DNA adduct formation after acute oral exposure of F-344 rats to fluoranthene. J Nutr Biochem 18: 236–249. 10.1016/j.jnutbio.2006.04.001 16781860
Wang, NC; Zhao, QJ; Wesselkamper, SC; Lambert, JC; Petersen, D; Hess-Wilson, JK. (2012). Application of computational toxicological approaches in human health risk assessment. I. A tiered surrogate approach. Regul Toxicol Pharmacol 63: 10–19. 10.1016/j.yrtph.2012.02.006 22369873
White, GL; Fu, PP; Heflich, RH. (1985a). Effect of nitro substitution on the light-mediated mutagenicity of polycyclic aromatic hydrocarbons in salmonella typhimurium TA98. Mutat Res 144: 1–7. 10.1016/0165-7992(85)90115-0 3897840
White, KL; Holsapple, MP. (1984). Direct suppression of in vitro antibody production by mouse spleen cells by the carcinogen benzo(a)pyrene but not by the noncarcinogenic congener benzo(e)pyrene. Cancer Res 44: 3388–3393.6331644
White, KL; Lysy, HH; Holsapple, MP. (1985b). Immunosuppression by polycyclic aromatic hydrocarbons: A structure-activity relationship in B6C3F1 and DBA/2 mice. Immunopharmacology 9: 155–164. 10.1016/0162-3109(85)90011-6 4040508
White, KL; McLoughlin, CE; Auttachoat, W; Smith, MJ. (2012). Validation of the Candida albicans delayed-type hypersensitivity (DTH) model in the female B₆C₃F₁ mouse for use in immunotoxicological investigations. J Immunotoxicol 9: 141–147. 10.3109/1547691X.2011.636768 22339419
WHO (World Health Organization). (1998). Environmental Health Criteria 202: Selected non-heterocyclic policyclic aromatic hydrocarbons [WHO EHC]. Geneva, Switzerland. http://www.inchem.org/documents/ehc/ehc/ehc202.htm#SubSectionNumber:4.2.1
Winker, N; Tuschl, H; Kovac, R; Weber, E. (1997). Immunological investigations in a group of workers exposed to various levels of polycyclic aromatic hydrocarbons. J Appl Toxicol 17: 23–29.9048224
Wojdani, A; Alfred, LJ. (1984). Alterations in cell-mediated immune functions induced in mouse splenic lymphocytes by polycyclic aromatic hydrocarbons. Cancer Res 44: 942–945.6420057
Wojdani, A; Attarzadeh, M; Wolde-Tsadik, G; Alfred, LJ. (1984). Immunocytotoxicity effects of polycyclic aromatic hydrocarbons on mouse lymphocytes. Toxicology 31: 181–189.6330935
Wood, AW; Levin, W; Thakker, DR; Yagi, H; Chang, RL; Ryan, DE; Thomas, PE; Dansette, PM; Whittaker, N; Turujman, S; Lehar, RE; Kumar, S; Jerina, DM; Conney, AH. (1979). Biological activity of benzo[e]pyrene. An assessment based on mutagenic activities and metabolic profiles of the polycyclic hydrocarbon and its derivatives. J Biol Chem 254: 4408–4415.374411
Wynder, EL; Hoffmann, D. (1959). A study of tobacco carcinogenesis. VII. The role of higher polycyclic hydrocarbons. Cancer 12: 1079–1086. 10.1002/1097-0142(195911/12)12:6<1079::aid-cncr2820120604>3.0.co;2-i 13846285
Zeiger, E; Anderson, B; Haworth, S; Lawlor, T; Mortelmans, K. (1992). Salmonella mutagenicity tests: V. Results from the testing of 311 chemicals. Environ Mol Mutagen 19: 2–141. 10.1002/em.2850190603 1541260
Zhao, W; Ramos, KS. (1995). Inhibition of DNA synthesis in primary cultures of adult rat hepatocytes by benzo[a]pyrene and related aromatic hydrocarbons: Role of Ah receptordependent events. Toxicology 99: 179–189. 10.1016/0300-483X(94)03028-Z 7610464