# APPENDIX C RESULTS OF THE SCREENING EVALUATION OF POTENTIAL CARCINOGENICITY

## STEP 1 USE OF AUTOMATED TOOLS TO IDENTIFY STRUCTURAL ANALOGUES WITH CARCINOGENICITY AND/OR GENOTOXICITY DATA

U.S. EPA’s Chemical Assessment Clustering Engine (ChemACE) clustering was performed as described in Appendix B. Using the most restrictive clustering rules (where ChemACE assigns a unique definition for each fragment, ensuring that each chemical submitted for clustering appears in only one ChemACE cluster), benzo[e]pyrene (BeP) appeared in Cluster 51, which contained seven additional compounds (benzo[g]chrysene, perylene, picene, benzo[b]chrysene, dibenz[a,c]anthracene, dibenzo[a,j]anthracene, and benzo[a]pyrene [BaP]). Using the less restrictive clustering option did not change the result (BeP found in a single cluster with seven other compounds).

The Organisation for Economic Co-operation and Development (OECD) Quantitative Structure-Activity Relationship (QSAR) Toolbox Profiler was used to identify structural analogues from the Dice analogue search with carcinogenicity and/or genotoxicity data (see Step 1 methods in Appendix B). The Dice analogue search identified >1,500 chemicals with ≥50% similarity to BeP; therefore, the similarity threshold was raised to 80%. The Dice analogue search identified 107 compounds with carcinogenicity and/or genotoxicity data and ≥80% similarity to BeP, including five of the seven compounds identified by ChemACE. Refinement of the selection of final analogues is described below.

## STEP 2 ANALOGUE REFINEMENT USING EXPERT JUDGMENT

Expert judgment was applied to refine the initial list of 109 potential analogues based on physicochemical properties; absorption, distribution, metabolism, and excretion (ADME); and mechanisms of toxicity.

BeP contains five unsubstituted benzene rings. Therefore, compounds were only considered as potential analogues if they were unsubstituted and contained five benzene rings. Of the 109 chemicals identified as potential analogues by ChemACE clustering and the OECD QSAR Toolbox analogue selection tool (Dice), 101 were not selected for further review, including:

- Polycyclic aromatic hydrocarbon (PAH) compounds with benzene ring number ≠ 5
- Compounds containing nonaromatic ring structures (e.g., benzo[b]fluoranthene)
- Substituted PAHs (e.g., alkyl, amino/nitro/nitroso or halogenated substituents)
- Hydroxyl PAH metabolites

Each of these attributes introduce significant differences in bioavailability, reactivity, and applicable metabolic pathways relative to BeP.

The remaining eight possible analogues for BeP are listed in Table C-1. The existence of a cancer toxicity value and/or a weight-of-evidence (WOE) determination for cancer is indicated for each analogue.

Table C-1 Summary of Cancer Assessment Information for Analogues of BeP (CASRN 192-97-2)

Analogue Name (CASRN)^a^ | Cancer Risk Estimates (if available) | WOE Determinations
BaP^a,^ ^b^ (50-32-8) | U.S. EPA (2017c)—OSF, IUR; CalEPA (2011)—OSF, IUR | U.S. EPA (2017c)—“Carcinogenic to Humans”; IARC (2010)—carcinogenic to humans (Group 1)
BbC^a,^ ^b^ (214-17-5) | None | IARC (2010)—not classifiable as to their carcinogenicity to humans (Group 3)
BgC^a^ (196-78-1) | None | IARC (2010)—not classifiable as to their carcinogenicity to humans (Group 3)
DBacA^a^ (215-58-7) | None | IARC (2010)—not classifiable as to their carcinogenicity to humans (Group 3)
DBahA^b^ (53-70-3) | CalEPA (1992), CalEPA (2019)—OSF, IUR | U.S. EPA (1990c)—probable human carcinogen (Group B2); IARC (2010)—probably carcinogenic to humans (Group 2A)
DBajA^a,^ ^b^ (224-41-9) | None | IARC (2010)—not classifiable as to their carcinogenicity to humans (Group 3)
Perylene^a,^ ^b^ (198-55-0) | None | U.S. EPA (2007)—“Inadequate Information to Assess Carcinogenic Potential”; IARC (2010)—not classifiable as to their carcinogenicity to humans (Group 3)
Picene^a,^ ^b^ (213-46-7) | None | IARC (2010)—not classifiable as to their carcinogenicity to humans (Group 3)

a Found by ChemACE.

b Found by Dice.

BaP = benzo[a]pyrene; BbC = benzo[b]chrysene; BeP = benzo[e]pyrene; BgC = benzo[g]chrysene; DBacA = dibenz[a,c]anthracene; DBahA = dibenz[a,h]anthracene; DBajA = dibenzo[a,j]anthracene; IUR = inhalation unit risk; OSF = oral slope factor; WOE = weight of evidence.

## STEP 3 COMPARISON OF THE EXPERIMENTAL GENOTOXICITY DATA FOR BEP AND ANALOGUES

The genotoxicity data available for BeP are described in the “Other Data” section in the main body of this report. Available data indicate that BeP is weakly mutagenic following metabolic activation but not mutagenic without activation. Most studies indicate that BeP is not clastogenic and does not cause deoxyribonucleic acid (DNA) damage; however, BeP (or a metabolite) is capable of forming DNA adducts, and there is inconsistent evidence from in vivo studies indicating that BeP is capable of causing chromosomal damage under certain conditions. Genotoxicity data for the analogue compounds have been extensively reviewed. A summary of the genotoxicity data for analogue PAHs is provided in Table C-2. Overall data indicate that these analogues are mutagenic and clastogenic, and capable of binding DNA and causing DNA damage. Numerous studies have reported a weak genotoxic potential of BeP in vitro compared with other PAHs, including analogues BaP, dibenz[a,c]anthracene (DBacA), dibenz[a,h]anthracene (DBahA), dibenz[a,j]anthracene (DBajA), and, in some assays, perylene (Durant et al., 1996; Mersch-Sundermann et al., 1993; Mersch-Sundermann et al., 1992; De Flora et al., 1984; Haas et al., 1981; Kaden et al., 1979; Simmon, 1979; Andrews et al., 1978; McCann et al., 1975).

Table C-2 Comparison of Available Genotoxicity Data for BeP (CASRN 192-97-2) and Analogues

Chemical (CASRN) | Mutagenicity | Clastogenicity | DNA Damage and Adducts | Cell Transformation | Reference
BeP | - Weakly mutagenic in Salmonella typhimurium with metabolic activation; not mutagenic without activation; - Not mutagenic in Escherichia coli; - Mutagenic in mammalian cells with metabolic activation only at cytotoxic concentrations | - Predominantly negative in mammalian cells in vitro; - Mixed results in vivo (induced CAs in rats but not hamsters, induced SCEs in hamsters, negative for MN in mice) | - Predominantly negative for DNA damage/repair assays in vitro and in vivo; - DNA adducts measured in mammalian cells and isolated human DNA | - Weak induction of cell transformation in mammalian cells in vitro | See Table 4A
BaP; (50-32-8) | - Mutagenic in S. typhimurium and E. coli; - Mutagenic in mammalian cells in vitro; - Induced somatic and sex-linked recessive mutations in Drosophila melanogaster; - Mutagenic in dominant lethal and transgenic mouse studies; - K-ras and p53 mutations in human tumor tissues | - Induced SCEs, CAs, and MNs in mammalian cells in vitro and in vivo | - DNA damage/repair in E. coli; - Induced DNA damage/repair in mammalian cells in vitro and in vivo; - DNA adducts measured in mammalian cells | - Induced neoplastic transformation in mammalian cells | De Flora et al. (1984); U.S. EPA (2017c); U.S. EPA (2017b)
BbC; (214-17-5) | ND | ND | ND | ND | NA
BgC; (196-78-1) | - BgC 11,12-diol-13,14-oxides mutagenic in S. typhimurium and E. coli; - BgC 11,12-diol-13,14-oxides mutagenic in mammalian cells in vitro | ND | - DNA adducts of BgC 11,12-diols and BgC 11,12-diol-13,14-oxides in mouse skin; - CYP-activated BgC 11,12-diols cause DNA damage in cDNA-based recombinant (E. coli or Trichoplusia ni) systems | ND | IARC (2010)
DBacA; (215-58-7) | - Mutagenic in S. typhimurium; - Mutagenic in mammalian cells in vitro; - DBacA 10,11-dihydrodiol mutagenic in bacteria | - Negative for SCE in mammalian cells in vitro (single study) | - DNA damage in Bacillus subtilis; - DNA damage in mammalian cells in vitro; - DNA adducts in mammalian cells in vitro | - Cell transformation in mammalian cells in vitro | IARC (1983)
DBahA; (53-70-3) | - DBahA, DBahA, 3,4-diol, and DBahA 3,4:10,11-bisdiol mutagenic in S. typhimurium; - DBahA mutagenic in mammalian cells in vitro | - Induced MN in mammalian cells in vivo and SCEs and MN in mammalian cells in vitro | - DNA adducts of DBahA 3,4-diol-1,2-oxide and DBahA 3,4:10,11-bisdiol in vitro and/or in vivo | - DBahA 3,4-diol and DBahA 3,4-diol-1,2-oxide induced morphological cell transformation in mammalian cells | IARC (2010)
DBajA; (224-41-9) | - Mutagenic in S. typhimurium; - Mutagenic in human lymphoblastoid cells; - DBajA 3,4-diol-1,2-oxide mutagenic in E. coli | ND | - DNA adducts of DBajA diols, bisdiols, and oxides in vivo | ND | IARC (2010)
Perylene; (198-55-0) | - Mutagenic in S. typhimurium; - Not mutagenic in human lymphoblastoid cells | - CAs in mammalian cells in vitro | - Negative for DNA damage/repair in E. coli | ND | De Flora et al. (1984); IARC (1983)
Picene; (213-46-7) | - Not mutagenic in S. typhimurium; - Not mutagenic in human lymphoblastoid cells | ND | ND | ND | Durant et al. (1996); Kaden et al. (1979)

BaP = benzo[a]pyrene; BbC = benzo[b]chrysene; BeP = benzo[e]pyrene; BgC = benzo[g]chrysene; CA = chromosomal aberration; DBacA = dibenz[a,c]anthracene; DBahA = dibenz[a,h]anthracene; DBajA = dibenz[a,j]anthracene; DNA = deoxyribonucleic acid; MN = micronuclei; ND = no data; SCE = sister chromatid exchange.

## STEP 4 TOXICOKINETICS OF BEP AND ANALOGUES

The toxicokinetics of BeP and potential analogues are briefly described in Table C-3.

No data on absorption or distribution are available for BeP or any analogue with the exception of BaP. BaP absorption and distribution are extensively reviewed by U.S. EPA (2017b), IARC (2010), and ATSDR (1995). BaP is absorbed via inhalation, oral, and dermal routes. The rate of inhalation absorption is dependent on numerous factors, including particle size, region of deposition, and rate of dissolution or desorption from particles, with rapid absorption occurring through thin alveolar epithelium and slower absorption in thicker regions of the airways. Inhaled BaP is also transported to the gut via the mucociliary escalator. Gastrointestinal absorption of BaP ranges from 10 to 60%, with enhanced absorption in the presence of lipophilic compounds. Dermal absorption is rapid and near complete when administered in crude oil or acetone, with decreased absorption if administered in high-viscosity oil vehicles or in soils with high organic carbon content. Following absorption, BaP shows rapid, widespread systemic distribution followed by accumulation and retention in fat. Because absorption and distribution of a chemical in the body are determined largely by physical and chemical properties related to its molecular size and general structure (e.g., lipophilicity, vapor pressure, etc.), it is reasonable to assume that BeP and other PAH analogues will be absorbed and distributed similarly to BaP based on similar size, structure, and physicochemical properties.

In general, PAHs (including BeP and analogues) are oxidized by cytochrome P450 (CYP450) in multiple tissues in the body to more soluble metabolites, including dihydrodiols, phenols, quinones, and epoxides, which then form conjugates with glucuronide, glutathione (GSH), or sulfate (U.S. EPA, 2017b; IARC, 2010; ATSDR, 1995). While PAHs share similar metabolic pathways, there are differences in the primary metabolic products that can affect carcinogenic potential (see “Metabolism/Toxicokinetic Studies” section and Table C-3 for more details). For example, in contrast to BaP (the most well-studied carcinogenic PAH), there is minimal evidence for bay-region activation of BeP in rodent model systems and generation of the 9,10-dihydrodiol metabolite, and subsequent formation of the DNA reactive epoxide is described as limited within this model system (Jacob et al., 1985; Jacob et al., 1983; Wood et al., 1979). Data support the notion that production of the 9,10-dihydrodiol metabolite is increased in human model systems, but the extent and consequence of production of the DNA reactive epoxide metabolite in humans remains uncertain.

No excretion data are available for BeP or any analogue, with the exception of BaP (see Table C-3). BaP excretion has been extensively reviewed by U.S. EPA (2017b), IARC (2010), and ATSDR (1995). Excretion of BaP, primarily as conjugated metabolites, is rapid and occurs primarily via biliary excretion to feces, with small amounts excreted in urine. Because PAHs share common metabolic profiles, it is reasonable to assume that conjugated metabolites of BeP and other PAH analogues will be excreted similarly to BaP.

Table C-3 Summary of Toxicokinetic Data for BeP (CASRN 192-97-2) and Analogues

Compound (CASRN) | Absorption, Distribution, Excretion | Metabolism | References
BeP; (192-97-2) | ND | - Metabolism is rapid (complete within 48 h); - Oxidized via CYP450 to the k-region 4,5-dihydrodiol, phenols and quinones; - Oxidative metabolism can be induced by CYP450 inducers; - Bay-region 9,10-dihydrodiol is formed in small amounts and then preferentially oxidized at the 4,5-position, rather than forming the 9,10-expoxide; - Oxidative metabolites conjugated with glucuronic acid | See “Other Data” section of this document.
BaP; (50-32-8) | Absorption:; - Absorbed by oral, inhalation, and dermal exposure; - Rate and extent of absorption is variable, depending on exposure medium (e.g., oral and dermal absorption enhanced in presence of oils and fats; dermal absorption decreased in presence of soils with high organic carbon content); - Significant mucociliary clearance of inhaled particulate to gut; - Absorption from gut depends on presence of bile in intestinal lumen; Distribution:; - Widely distributed throughout the body; - Initial rapid uptake into well-perfused tissues (e.g., lung, kidney, liver); - Subsequent accumulation, retention, and slow release from fat; - High levels in gut (from any route) due to mucociliary clearance from respiratory tract and hepatobiliary excretion of metabolites; - Limited placental transfer; Excretion:; - Excretion is rapid, with half-times of 22−30 h; - Primary route is biliary excretion to feces; urine is secondary route; - Excreted mainly as conjugated metabolites; - Small amounts excreted in milk | - Metabolism is rapid and occurs in many tissues throughout the body; - Oxidized via CYP450; primary metabolites are 9,10-, 7,8-, 4,5-, and 2,3-dihydrodiols and epoxides, as well as various phenols, quinones, and derivatives.; - Oxidative metabolism can be induced by CYP450 inducers; - Oxidative metabolites conjugated with GSH, glucuronic acid, and sulfate esters | ATSDR (1995); IARC (2010); U.S. EPA (2017b); U.S. EPA (2017c)
BbC; (214-17-5) | ND | ND | NA
BgC; (196-78-1) | ND | - Fjord region oxidation to form 11,12-diols; - Further metabolism via intermediary 11,12-diol-13,14-oxides to form diastereomeric tetrols | IARC (2010)
DBacA; (215-58-7) | ND | - Oxidation to 10,11-dihydrodiol (major metabolite); - Further oxidation to 10,11-diol-12,13-epoxide; - Minor metabolites include 1,2- and 3,4-diols | IARC (1983)
DBahA; (53-70-3) | ND | - Metabolic activation via the diol epoxide mechanism to diols, oxides, catechols, phenols, and hexols | IARC (2010)
DBajA; (224-41-9) | ND | - Metabolic activation via the diol epoxide mechanism to diols, bisdiols, and oxides; - Glucuronidation of diols | IARC (2010)
Perylene; (198-55-0) | ND | ND | NA
Picene; (213-46-7) | ND | - Primary metabolites formed via oxidation include dihydrodiols, phenols, and quinones | Platt et al. (1988)

BaP = benzo[a]pyrene; BbC = benzo[b]chrysene; BeP = benzo[e]pyrene; BgC = benzo[g]chrysene; CYP450 = cytochrome P450; DBacA = dibenz[a,c]anthracene; DBahA = dibenz[a,h]anthracene; DBajA = dibenz[a,j]anthracene; GSH = glutathione; NA = not applicable; ND = no data.

## STEP 5 CARCINOGENICITY OF BEP ANALOGUES AND MOA DISCUSSION

U.S. EPA cancer WOE descriptors for BeP and analogue compounds are shown in Tables C-4 (oral) and C-5 (inhalation). As noted in the PPRTV document, there is inadequate information to assess the carcinogenic potential of BeP by oral or inhalation exposure. Only two of the potential analogue compounds are characterized as having evidence of carcinogenic potential. Additionally, several potential analogues have been identified as unmeasured components of complex chemical mixtures that are known to be carcinogenic in humans. BaP was characterized as “Carcinogenic to Humans” (U.S. EPA, 2017c) under the 2005 Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005) and DBahA was considered a probable human carcinogen (U.S. EPA, 1993) under the 1986 Guidelines for Carcinogen Risk Assessment (U.S. EPA, 1986). Reported oral slope factor (OSF) and inhalation unit risk (IUR) values were two- to threefold higher for DBahA compared with BaP.

Table C-4 Comparison of Available Oral Carcinogenicity Toxicity Data for BeP (CASRN 192-97-2) and Analogues

Type of Data | BeP | BaP | BbC | BgC | DBacA | DBahA | DBajA | Perylene | Picene
Structure | 2D chemical structure of 192-97-2 | 2D chemical structure of 50-32-8 | 2D chemical structure of 214-17-5 | 2D chemical structure of 196-78-1 | structure diagram | structure diagram | 2D chemical structure of 224-41-9 | structure diagram | 2D chemical structure of 213-46-7
CASRN | 192-97-2 | 50-32-8 | 214-17-5 | 196-78-1 | 215-58-7 | 53-70-3 | 224-41-9 | 198-55-0 | 213-46-7
U.S. EPA WOE characterization | “Inadequate Information to Assess Carcinogenic Potential” | “Carcinogenic to Humans” | ND | ND | ND | Probable human carcinogen (Group B2) | ND | “Inadequate Information to Assess Carcinogenic Potential” | ND
OSF (mg/kg-d)^−1^ | NDr | 1.4 | NDr | NDr | NDr | 4.12 | NDr | NDr | NDr
Data set(s) used for slope factor derivation | ND | Alimentary tract tumors (multiple sites) in female B6C3F1 mice | ND | ND | ND | Pulmonary (alveolar carcinomas) | ND | ND | ND
Other tumors observed in animal oral bioassays | ND | Auditory canal, kidney, liver, skin, mammary gland | ND | ND | ND | Mammary, forestomach, hemangio-endothelioma | ND | ND | ND
Study doses (mg/kg-d) | ND | 0, 0.7, 3.3, 16.5 | ND | ND | ND | NS | ND | ND | ND
Route (method) | ND | Oral (diet) | ND | ND | ND | NS | ND | ND | ND
Duration | ND | 2 yr | ND | ND | ND | NS | ND | ND | ND
POD type | ND | BMDL_10_ 0.071 mg/kg-d | ND | ND | ND | NS | ND | ND | ND
Source | NA | U.S. EPA (2017b); U.S. EPA (2017c) | NA | NA | NA | U.S. EPA (1990c); CalEPA (2019); CalEPA (1992) | NA | NA | NA

BaP = benzo[a]pyrene; BbC = benzo[b]chrysene; BeP = benzo[e]pyrene; BgC = benzo[g]chrysene; BMDL = benchmark dose lower confidence limit; DBacA = dibenz[a,c]anthracene; DBahA = dibenz[a,h]anthracene; DBajA = dibenz[a,j]anthracene; NA = not applicable; ND = no data; NDr = not determined; NS = not specified; OSF = oral slope factor; POD = point of departure; WOE = weight of evidence.

Table C-5 Comparison of Available Inhalation Carcinogenicity Toxicity Data for BeP (CASRN 192-97-2) and Analogues

Type of Data | BeP | BaP | BbC | BgC | DBacA | DBahA | DBajA | Perylene | Picene
Structure | 2D chemical structure of 192-97-2 | 2D chemical structure of 50-32-8 | 2D chemical structure of 214-17-5 | 2D chemical structure of 196-78-1 | structure diagram | structure diagram | 2D chemical structure of 224-41-9 | structure diagram | 2D chemical structure of 213-46-7
CASRN | 192-97-2 | 50-32-8 | 214-17-5 | 196-78-1 | 215-58-7 | 53-70-3 | 224-41-9 | 198-55-0 | 213-46-7
U.S. EPA WOE characterization | “Inadequate Information to Assess Carcinogenic Potential” | “Carcinogenic to Humans” | ND | ND | ND | Probable human carcinogen (Group B2) | ND | “Inadequate Information to Assess Carcinogenic Potential” | ND
IUR (μg/m^3^)^−1^ | NDr | 0.0006 | NDr | NDr | NDr | 0.00122 | NDr | NDr | NDr
Data set(s) used for unit risk derivation | ND | Squamous cell neoplasia in upper respiratory tract (multiple sites), esophagus, and forestomach of male Syrian golden hamster | ND | ND | ND | NS | ND | ND | ND
Other tumors observed in animal inhalation bioassays | ND | ND | ND | ND | ND | ND | ND | ND | ND
Study concentrations (mg/m^3^) | ND | 0, 2.2, 9.5, 46.5 | ND | ND | ND | NS | ND | ND | ND
Route (method) | ND | Inhalation (nose only) | ND | ND | ND | NS | ND | ND | ND
Duration | ND | Up to 130 wk | ND | ND | ND | NS | ND | ND | ND
POD type | ND | BMCL_10_ 0.163 mg/m^3^ | ND | ND | ND | NS | ND | ND | ND
Source | NA | U.S. EPA (2017b); U.S. EPA (2017c) | NA | NA | NA | U.S. EPA (1990c); CalEPA (2019) | NA | NA | NA

BaP = benzo[a]pyrene; BbC = benzo[b]chrysene; BeP = benzo[e]pyrene; BgC = benzo[g]chrysene; BMCL = benchmark concentration lower confidence limit; DBacA = dibenz[a,c]anthracene; DBahA = dibenz[a,h]anthracene; DBajA = dibenz[a,j]anthracene; IUR = inhalation unit risk; NA = not applicable; ND = no data; NDr = not determined; NS = not specified; POD = point of departure; WOE = weight of evidence.

As summarized in Tables C-4 (oral) and C-5 (inhalation), BaP is a multisite carcinogen in laboratory animals following oral and inhalation exposure and DBahA is a multisite carcinogen in laboratory animals following oral exposure. No oral or inhalation carcinogenicity data are available for BeP or analogues other than BaP and DBahA. However, data from other routes (e.g., dermal, injection, implantation) are available for all compounds except benzo[g]chrysene (BgC) (see Table C-6). For BeP, evidence of carcinogenicity from other route studies is limited to a positive finding for skin tumor initiation in one of six dermal initiation-promotion studies; BeP was not carcinogenic in complete dermal, injection, or implantation studies. When metabolites were tested directly, 9,10-dihydrobenzo[e]pyrene was a skin tumor initiator and the 9,10-dihydrodiol and a diol epoxide induced hepatic tumors in neonatal injection studies (metabolite studies not included in Table C-6). For analogues, BaP and DBahA are the best studied and demonstrate consistent carcinogenic potential across exposure routes. Most other PAH analogues (benzo[b]chrysene, DBacA, DBajA, and picene) show evidence of carcinogenicity in a limited number of studies; however, perylene shows negative or equivocal findings in dermal and injection studies.

The U.S. EPA (2017c) proposed a mutagenic MOA for BaP carcinogenicity via all routes of exposure. Proposed key events include (1) metabolism of BaP into DNA-reactive metabolites (diol epoxides, radical cations, and o-quinone and reactive oxygen species [ROS]), (2) direct DNA damage via DNA adducts and ROS-mediated damage, (3) DNA mutation, and (4) clonal expansion of mutated cells. Alternative MOAs that may contribute to tumor promotion include aryl hydrocarbon receptor (AhR) affinity, immune suppression, cytotoxicity and inflammation, and inhibition of gap junctional intercellular communication (U.S. EPA, 2017c). IARC (2010) also proposed that the formation of DNA-reactive diol epoxides during metabolism of PAHs underlies carcinogenic potential. A mutagenic MOA is plausible for all analogues, as well as BeP, especially those that have demonstrated mutagenic potential and DNA adduct formation (BeP, BgC, DBacA, DBahA, and DBajA) (see Table C-2).

Table C-6 Summary of Carcinogenicity Studies Using Other Exposure Routes for BeP (CASRN 192-97-2) Analogues

Exposure Route (species) | BeP^a^; 192-97-2 | BaP^b^; 50-32-0 | BbC^b^; 214-17-5 | BgC^b^; 196-78-1 | DBacA^b^; 215-58-7 | DBahA^b^; 53-70-3 | DBajA^b^; 224-41-9 | Perylene^b^; 198-55-0 | Picene^b^; 213-46-7
Dermal (mouse)
Dermal (mouse) | | Sk | | | Sk | Sk | Sk | | Sk
Dermal initiation promotion (mouse)
Dermal initiation promotion (mouse) | Sk | Sk | Sk | | Sk | Sk | Sk | (Sk) | Sk
i.v. Injection (mouse)
i.v. Injection (mouse) | | | | | | Lu
i.p. Injection (mouse)
i.p. Injection (mouse) | | Lu, Lv, St | | | (Lv) | Lu
i.p. Injection (rat)
i.p. Injection (rat) | | Ms
s.c. Injection (mouse)
s.c. Injection (mouse) | | IS, Lu | | | | IS, Lu | (IS) | | IS, Lu
s.c. Injection (rat)
s.c. Injection (rat) | | IS | | | | IS
Intratracheal (hamster)
Intratracheal (hamster) | | Lu, OR | | | | OR
Intratracheal (rat or mouse)
Intratracheal (rat or mouse) | | Lu
Intrapulmonary (rat)
Intrapulmonary (rat) | | Lu | | | | Lu
Intrapulmonary (mouse)
Intrapulmonary (mouse) | | | | | | Lu
Buccal pouch application (hamster)
Buccal pouch application (hamster) | | BP, St
Intramammary, intramamillary (rat)
Intramammary, intramamillary (rat) | | Mm

Color Key:

Experiments in this test system | 1 to 2 | 3 to 5 | ≥6
Experiments reporting statistically significant increase | 1 to 2 | 3 to 5 | ≥6
Experiments reporting equivocal result | (+/−)

Tumor Site Key:

BP = buccal pouch; IS = injection site; Lu = lung; Lv = liver; Mm = mammary; Ms = mesothelioma, abdominal; OR = other respiratory tract; Sk = skin; St = forestomach, stomach.

a See Table 3B in main document for BeP references.

b Data obtained from IARC (2010).

BaP = benzo[a]pyrene; BbC = benzo[b]chrysene; BeP = benzo[e]pyrene; BgC = benzo[g]chrysene; DBacA =dibenz[a,c]anthracene ; DBahA = dibenz[a,h]anthracene; DBajA = dibenzo[a,j]anthracene; i.p. = intraperitoneal; s.c. = subcutaneous.

## STEP 6 STRUCTURAL ALERTS AND SAR PREDICTIONS FOR BEP AND ANALOGUES

Structural alerts and predictions for genotoxicity and carcinogenicity were identified using computational tools as described in Appendix B. The model results for BeP and its analogue compounds are shown in Table C-7. Concerns for carcinogenicity and/or mutagenicity of BeP and its analogues were indicated by several models within each predictive tool (see Table C-7). Table C-8 provides a list of the specific structural and mechanistic alerts that underlie the findings of a concern for carcinogenicity or mutagenicity in Table C-7. These include a structural alert for PAHs and mechanistic alerts for DNA alkylation and intercalation.

Table C-7 Heat Map Illustrating the Structural Alert and SAR Prediction Results for BeP (CASRN 192-97-2) and Analogues^a^

Tool | Model^b^ | BeP | BaP | BbC | BgC | DBacA | DBahA | DBajA | Perylene | Picene
Mutagenicity/genotoxicity alerts
OECD QSAR Toolbox | DNA alerts for Ames by OASIS
OECD QSAR Toolbox | DNA alerts for CA and MNT by OASIS
OECD QSAR Toolbox | In vitro mutagenicity (Ames test) alerts by ISS
OECD QSAR Toolbox | In vivo mutagenicity (MN) alerts by ISS
OECD QSAR Toolbox | Protein binding alerts for chromosomal aberration by OASIS
ToxRead | ToxRead (mutagenicity)
VEGA | Mutagenicity (Ames test) CONSENSUS model—assessment
VEGA | Mutagenicity (Ames test) model (CAESAR)—assessment
VEGA | Mutagenicity (Ames test) model (SARpy/IRFMN)—assessment
VEGA | Mutagenicity (Ames test) model (ISS)—assessment
VEGA | Mutagenicity (Ames test) model (k-NN/read-across)—assessment
Toxtree | Potential Salmonella typhimurium TA100 mutagen based on QSAR
Toxtree | Unlikely to be a S. typhimurium TA100 mutagen based on QSAR
Carcinogenicity alerts
OECD QSAR Toolbox | Carcinogenicity (genotoxicity and nongenotoxicity) alerts by ISS
OncoLogic | OncoLogic (prediction of the carcinogenic potential of the chemical)
VEGA | Carcinogenicity model (CAESAR)—assessment
VEGA | Carcinogenicity model (ISS)—assessment
VEGA | Carcinogenicity model (IRFMN/ANTARES)—assessment
VEGA | Carcinogenicity model (IRFMN/ISSCAN-CGX)—assessment
VEGA | Carcinogenicity oral classification model (IRFMN)
VEGA | Carcinogenicity inhalation classification model (IRFMN)
ToxAlerts | Polycyclic aromatic hydrocarbons (for nongenotoxic carcinogenicity)
Toxtree | Potential carcinogen based on QSAR
Toxtree | Unlikely to be a carcinogen based on QSAR
Toxtree | Nongenotoxic carcinogenicity
Combined alerts
ToxAlerts | Polycyclic aromatic hydrocarbons (for genotoxic carcinogenicity)
Toxtree | Structural alert for genotoxic carcinogenicity
| ^b^Model results or alerts indicating no concern for carcinogenicity/mutagenicity.
| ^b^Model results outside the applicability domain for carcinogenicity/mutagenicity.
| ^b^Model results or alerts indicating concern for carcinogenicity/mutagenicity.

a All tools and models described in Appendix B were used. Models with results are presented in the heat map (models without results were omitted).

ANTARES = Alternative Non-Testing Methods Assessed for REACH Substances; BaP = benzo[a]pyrene; BbC = benzo[b]chrysene; BeP = benzo[e]pyrene; BgC = benzo[g]chrysene; CA = chromosomal aberration; CAESAR = Computer-Assisted Evaluation of industrial chemical Substances According to Regulations; CONSENSUS = consensus assessment based on multiple models (CAESAR, SARpy, ISS, and k-NN); DBacA = dibenz[a,c]anthracene; DBahA = dibenz[a,h]anthracene; DBajA = dibenz[a,j]anthracene; DNA = deoxyribonucleic acid; IRFMN = Istituto di Ricerche Farmacologiche Mario Negri; ISS = Istituto Superiore di Sanità; ISSCAN-CGX = Istituto Superiore di Sanità Chemical Carcinogen; k-NN = k-nearest neighbor; MN = micronucleus; MNT = micronucleus test; OECD = Organisation for Economic Co-operation and Development; REACH = Registration, Evaluation, Authorisation and Restriction of Chemicals; SAR = structure-activity relationship; QSAR = quantitative structure-analysis relationship; VEGA = Virtual models for property Evaluation of chemicals within a Global Architecture.

Table C-8 Structural Alerts and Chemical Mechanisms for BeP (CASRN 192-97-2) and Analogues

Structural Alert | Tools | Compounds
PAHs | OECD QSAR Toolbox | BeP, BaP, BbC, BgC, DBacA, DBahA, DBajA, perylene, picene
PAHs | ToxAlerts | BeP, BaP, BbC, BgC, DBacA, DBahA, DBajA, perylene, picene
PAHs | Toxtree | BeP, BaP, BbC, BgC, DBacA, DBahA, DBajA, perylene, picene
PAHs | OncoLogic | BaP, BgC, DBajA, picene
Mechanistic Alert | Tools | Compounds
DNA intercalation | OECD QSAR Toolbox | BbC, BgC, DBacA, DBahA, DBajA, picene
Alkylation after metabolically formed carbenium ion species | OECD QSAR Toolbox | BbC, BgC, DBacA, DBahA, DBajA, picene
Alkylation, direct acting epoxides and related after CYP450-mediated metabolic activation | OECD QSAR Toolbox | BbC, BgC, DBacA, DBahA, DBajA, picene

BaP = benzo[a]pyrene; BbC = benzo[b]chrysene; BeP = benzo[e]pyrene; BgC = benzo[g]chrysene; CYP450 = cytochrome P450; DBacA = dibenz[a,c]anthracene; DBahA = dibenz[a,h]anthracene DBajA = dibenz[a,j]anthracene; DNA = deoxyribonucleic acid; OECD = Organisation for Economic Co-operation and Development; PAH = polycyclic aromatic hydrocarbon; QSAR = quantitative structure-activity relationship.

## STEP 7 EVIDENCE INTEGRATION FOR SCREENING EVALUATION OF BEP CARCINOGENICITY

Table C-9 presents the data for multiple lines of evidence pertinent to the screening evaluation of the carcinogenic potential of BeP.

Table C-9 Integration of Evidence for BeP (CASRN 192-97-2) and Analogues

Evidence Streams | BeP | BaP | BbC | BgC | DBacA | DBahA | DBajA | Perylene | Picene
Structure | 2D chemical structure of 192-97-2 | 2D chemical structure of 50-32-8 | 2D chemical structure of 214-17-5 | 2D chemical structure of 196-78-1 | structure diagram | structure diagram | 2D chemical structure of 224-41-9 | structure diagram | 2D chemical structure of 213-46-7
CASRN | 192-97-2 | 50-32-8 | 214-17-5 | 196-78-1 | 215-58-7 | 53-70-3 | 224-41-9 | 198-55-0 | 213-46-7
Analogue selection and evaluation (see Steps 1 and 2) | Target compound: PAH, five unsubstituted benzene rings | PAH, five unsubstituted benzene rings | PAH, five unsubstituted benzene rings | PAH, five unsubstituted benzene rings | PAH, five unsubstituted benzene rings | PAH, five unsubstituted benzene rings | PAH, five unsubstituted benzene rings | PAH, five unsubstituted benzene rings | PAH, five unsubstituted benzene rings
Experimental genotoxicity data (see Step 3) | Weak mutagen with metabolic activation; predominately negative for clastogenicity and DNA damage/repair; forms DNA adducts; weak inducer of cell transformation | Mutagenic; clastogenic; DNA damaging; forms DNA adducts; induces cell transformation | ND | Mutagenic; DNA damaging; forms DNA adducts | Mutagenic; not clastogenic; DNA damaging; forms DNA adducts; induces cell transformation | Mutagenic; clastogenic; forms DNA adducts; induces cell transformation | Mutagenic; forms DNA adducts | Mutagenic in bacteria; not mutagenic in mammalian cells; clastogenic; does not cause DNA damage in bacteria | Not mutagenic
ADME evaluation (see Step 4) | Common metabolic pathways with other PAHs (oxidation and glucuronide conjugation); Metabolites: Major: k-region 4,5-dihydrodiol, phenols, and quinones; Minor: bay-region 9,10-dihydrodiol, 4,5,9,10-tetrahydroxy-4,5,9,10-tetrahydrobenzo[e]pyrene | Common metabolic pathways with other PAHs (oxidation and glucuronide, GSH, or sulfate conjugation); Metabolites: 9,10-, 7,8-, 4,5-, and 2,3-dihydrodiols and epoxides, as well as various phenols, quinones, and derivatives | Presumed common metabolic pathways with other PAHs (oxidation and glucuronide, GSH, or sulfate conjugation); Metabolites: ND | Common metabolic pathways with other PAHs (oxidation and glucuronide, GSH, or sulfate conjugation); Metabolites: fjord region 11,12-diols, 11,12-diol-12,14-oxides, diastereomeric tetrols | Common metabolic pathways with other PAHs (oxidation and glucuronide, GSH, or sulfate conjugation); Metabolites: Major: 10,11-dihydrodiol, 10,11-diol-12,13-epoxide; Minor: 1,2- and 3,4-diols | Common metabolic pathways with other PAHs (oxidation and glucuronide, GSH, or sulfate conjugation); Metabolites: diols, oxides, catechols, phenols, and hexols | Common metabolic pathways with other PAHs (oxidation and glucuronide conjugation); Metabolites: diols, bisdiols, oxides | Presumed common metabolic pathways with other PAHs (oxidation and glucuronide, GSH, or sulfate conjugation); Metabolites: ND | Common metabolic pathways with other PAHs (oxidation and glucuronide, GSH, or sulfate conjugation); Metabolites: dihydrodiols, phenols, and quinones
Cancer data and MOA (see Step 5) | No oral or inhalation data; Predominately negative in other route studies: tumor initiator in 1/6 studies, 1/5 metabolites was a dermal initiator, 2/7 metabolites induced tumors in injection studies; Inferred mutagenic MOA (based on BaP) | Multisite carcinogen in rodents following oral or inhalation exposure; Carcinogenic in other route studies; Proposed mutagenic MOA (U.S. EPA, 2017c) | No oral or inhalation data; Skin tumor promotion in dermal assays; Inferred mutagenic MOA (based on BaP) | ND | No oral or inhalation data; Skin tumors in dermal assays; limited data evidence for liver tumors in injection studies; Inferred mutagenic MOA (based on BaP) | Multisite carcinogen in rodents following oral exposure; Carcinogenic in other route studies; Inferred mutagenic MOA (based on BaP) | No oral or inhalation data; Skin tumors in dermal assays; limited evidence for injection site tumors; Inferred mutagenic MOA (based on BaP) | No oral or inhalation data; Equivocal evidence for skin tumors in dermal assays; negative in injection studies; Inferred mutagenic MOA (based on BaP) | No oral or inhalation data; Skin tumors in dermal assays; lung and injection site tumors in injection studies; Unknown MOA (negative in mutation assay)
Common structural alerts and SAR predictions (see Step 6) | Alerts:; - PAHs; SAR prediction:; Concerns for mutagenicity and carcinogenicity in most models | Alerts:; - PAHs; SAR prediction:; Concerns for mutagenicity and carcinogenicity in most models | Alerts:; - PAHs; - DNA intercalation; - Alkylation (metabolites); SAR prediction:; Concerns for mutagenicity and carcinogenicity in most models | Alerts:; - PAHs; - DNA intercalation; - Alkylation (metabolites); SAR prediction:; Concerns for mutagenicity and carcinogenicity in most models | Alerts:; - PAHs; - DNA intercalation; - Alkylation (metabolites); SAR prediction:; Concerns for mutagenicity and carcinogenicity in most models | Alerts:; - PAHs; - DNA intercalation; - Alkylation (metabolites); SAR prediction:; Concerns for mutagenicity and carcinogenicity in most models | Alerts:; - PAHs; - DNA intercalation; - Alkylation (metabolites); SAR prediction:; Concerns for mutagenicity and carcinogenicity in most models | Alerts:; - PAHs; SAR prediction:; Concerns for mutagenicity and carcinogenicity in most models | Alerts:; - PAHs; - DNA intercalation; - Alkylation (metabolites); SAR prediction:; Concerns for mutagenicity and carcinogenicity in most models

ADME = absorption, distribution, metabolism, and excretion; BaP. = benzo[a]pyrene; BbC = benzo[b]chrysene; BeP = benzo[e]pyrene; BgC = benzo[g]chrysene; DBacA = dibenz[a,c]anthracene; DBahA = dibenz[a,h]anthracene; DBajA = dibenz[a,j]anthracene; DNA = deoxyribonucleic acid; GSH = glutathione; MOA = mode of action; ND = no data; PAH = polycyclic aromatic hydrocarbon; SAR = structure-activity relationship.

## STEP 8 QUALITATIVE LEVEL OF CONCERN FOR BEP POTENTIAL CARCINOGENICITY

Table C-10 identifies the qualitative level of concern for potential carcinogenicity of BeP based on the multiple lines of evidence described above. Because the proposed mutagenic MOA for BaP is relevant for all exposure routes, a qualitative level of concern for BeP potential carcinogenicity is applicable to both oral and inhalation exposures.

Table C-10 Qualitative Level of Concern for Carcinogenicity of BeP (CASRN 192-97-2)

Level of Concern | Designation | Comments
Concern for potential carcinogenicity | Selected | Concern is based on (1) limited evidence of skin tumor initiation by BeP (at highest concentration tested), (2) limited evidence of skin tumor initiation by BeP metabolite 9,10-dihydrobenzo[e]pyrene, (3) limited evidence of tumor induction following neonatal i.p. exposure to specific BeP dihydrodiol and expected epoxide metabolites, (4) evidence of oral and/or inhalation carcinogenicity in animal studies of analogues BaP and DBahA, and (5) plausibility of a mutagenic MOA (potential, though limited, formation of reactive dihydrodiols and epoxides; evidence of mutagenicity with metabolic activation; formation of DNA adducts).
Inadequate information for assigning qualitative level of concern | NS | NA

BaP = benzo[a]pyrene; BeP = benzo[e]pyrene; DBahA = dibenz[a,h]anthracene; DNA = deoxyribonucleic acid; i.p. = intraperitoneal; MOA = mode of action; NA = not applicable; NS = not selected.