# AUTHORS, CONTRIBUTORS, AND REVIEWERS

## CHEMICAL MANAGER

- Robert Mitkus, PhD, DABT, ERT
  Center for Public Health and Environmental Assessment, Cincinnati, OH

## DRAFT DOCUMENT PREPARED BY

- SRC, Inc.
  7502 Round Pond Road
  North Syracuse, NY 13212

## CONTRIBUTORS

- Jay Zhao, MPH, PhD, DABT
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- John Stanek, PhD
  Center for Public Health and Environmental Assessment, Research Triangle Park, NC

## PRIMARY INTERNAL REVIEWERS

- Daniel D. Petersen, PhD, DABT
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- Laura Carlson, PhD
  Center for Public Health and Environmental Assessment, Research Triangle Park, NC

## PRIMARY EXTERNAL REVIEW

- Eastern Research Group, Inc.
  110 Hartwell Avenue
  Lexington, MA 02421-3136

## PPRTV PROGRAM MANAGEMENT

- Teresa L. Shannon
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- J. Phillip Kaiser, PhD, DABT
  Center for Public Health and Environmental Assessment, Cincinnati, OH

Questions regarding the content of this PPRTV assessment should be directed to the U.S. EPA Office of Research and Development (ORD) Center for Public Health and Environmental Assessment (CPHEA) website at https://ecomments.epa.gov/pprtv.