# 3 DERIVATION OF PROVISIONAL VALUES

## 3.1 DERIVATION OF PROVISIONAL REFERENCE DOSES

No adequate repeated-dose oral toxicity studies were identified for MAP or APP. The database of oral toxicity studies in animals exposed to DAP is limited to a German-language chronic study in rabbits evaluating only parathyroid weight [Fazekas (1954) as cited in Weiner et al. (2001)] and a combined 35-day repeated-dose toxicity and 28/53 days (males/females) reproductive/developmental screening study in rats [Huntingdon (2002) as cited in OECD (2007b) and ECHA (2002)]. The study by Fazekas (1954) as cited in Weiner et al. (2001) is not adequate for deriving a provisional reference dose (p-RfD). The study was published in German with only a brief summary reported in the review by Weiner et al. (2001); furthermore, the only endpoint evaluated was parathyroid gland weight, so effect levels could not be determined. The study by Huntingdon (2002) as cited in OECD (2007b) and ECHA (2002) was GLP-compliant, conducted according to OECD Test Guideline 422 (OECD, 1996), and evaluated numerous systemic (including neurological), reproductive, and developmental endpoints. This study was not published and is available as reported in secondary sources; therefore, this study was not considered suitable for deriving a p-RfD. However, the study was reviewed by both OECD HPV and ECHA, both of which are peer-review processes. The study appears to have been well conducted, was considered “reliable without restriction” by ECHA, and provides sufficient data to develop a screening-level subchronic p-RfD value for DAP (see Appendix A). Human and animal data are insufficient to derive a chronic p-RfD for ammonium phosphate salts, as discussed below.

## 3.2 DERIVATION OF PROVISIONAL REFERENCE CONCENTRATIONS

Human and animal data are insufficient to derive subchronic or chronic provisional reference concentrations (p-RfCs) for ammonium phosphate salts. The only available repeated-exposure information consists of a published occupational health study by Bhat and Ramaswamy (1993) and a NIOSH Human Hazard Evaluation (Ruhe and Ehrenberg, 1985); neither study evaluated ammonium phosphate exposure levels, precluding identification of effect levels.

## 3.3 SUMMARY OF NONCANCER PROVISIONAL REFERENCE VALUES

Table 5 presents a summary of noncancer provisional references values.

Table 5 Summary of Noncancer Reference Values for DAP (CASRN 7783-28-0) and MAP (CASRN 7722-76-1)

Toxicity Type (units) | Species/Sex | Critical Effect | p-Reference Value | POD Method | POD (HED) | UF_C_ | Principal Study
Screening subchronic p-RfD (mg DAP/kg-d) (see Appendix A) | Rat/both | Submucosal inflammation in stomach | 9 × 10^−2^ | BMDL_10_ | 27.7 | 300 | Huntingdon (2002) as cited in OECD (2007b) and ECHA (2002)
Chronic p-RfD (mg/kg-d) | NDr
Subchronic p-RfC (mg/m^3^) | NDr
Chronic p-RfC (mg/m^3^) | NDr

BMD = benchmark dose; BMDL = 95% benchmark dose lower confidence limit on the BMD (subscripts denote BMR: i.e., 10 = dose associated with 10% extra risk); BMR = benchmark response; DAP = diammonium phosphate; HED = human equivalent dose; MAP = monoammonium phosphate; NDr = not determined; POD = point of departure; p-RfC = provisional reference concentration; p-RfD = provisional reference dose; UF_C_ = composite uncertainty factor.

## 3.4 CANCER WEIGHT-OF-EVIDENCE DESCRIPTOR

Table 6 identifies the cancer weight-of-evidence (WOE) descriptor for MAP, DAP, and APP. No human or animal studies evaluating cancer endpoints are available for any of the chemicals. Limited in vitro genotoxicity assays of DAP and MAP available in peer-reviewed secondary sources (see Table 4) have reported negative results. Under the U.S. EPA (2005) cancer guidelines, the available data are inadequate for an assessment of human carcinogenic potential, and the cancer WOE descriptor for MAP, DAP, and APP is “Inadequate Information to Assess Carcinogenic Potential” (for both oral and inhalation routes of exposure).

Table 6 Cancer WOE Descriptor for Ammonium Phosphate Salts (MAP, CASRN 7722-76-1; DAP, CASRN 7783-28-0; and APP, CASRN 68333-79-9)

Possible WOE Descriptor | Designation | Route of Entry (oral, inhalation, or both) | Comments
“Carcinogenic to Humans” | NS | NA | There are no human carcinogenicity data identified to support this descriptor.
“Likely to Be Carcinogenic to Humans” | NS | NA | There are no animal carcinogenicity studies identified to support this descriptor.
“Suggestive Evidence of Carcinogenic Potential” | NS | NA | There are no animal carcinogenicity studies identified to support this descriptor.
“Inadequate Information to Assess Carcinogenic Potential” | Selected | Both | This descriptor is selected due to the lack of any information on carcinogenicity of MAP, DAP, and APP.
“Not Likely to Be Carcinogenic to Humans” | NS | NA | No evidence of noncarcinogenicity is available.

APP = ammonium polyphosphate; DAP = diammonium phosphate; MAP = monoammonium phosphate; NA = not applicable; NS = not selected; WOE = weight of evidence.

## 3.5 DERIVATION OF PROVISIONAL CANCER RISK ESTIMATES

Due to a lack of carcinogenicity data, derivation of cancer risk estimates is not supported (see Table 7).

Table 7 Summary of Cancer Risk Estimates for Ammonium Phosphate Salts (MAP, CASRN 7722-76-1; DAP, CASRN 7783-28-0; and APP, CASRN 68333-79-9)

Toxicity Type (units) | Species/Sex | Tumor Type | Cancer Risk Estimate | Principal Study
p-OSF (mg/kg-d)^−1^ | NDr
p-IUR (mg/m^3^)^−1^ | NDr

APP = ammonium polyphosphate; DAP = diammonium phosphate; MAP = monoammonium phosphate; NDr = not determined; p-IUR = provisional inhalation unit risk; p-OSF = provisional oral slope factor.