# APPENDIX D REFERENCES

ACGIH (American Conference of Governmental Industrial Hygienists). (2018). 2018 TLVs and BEIs: based on the documentation of the threshold limit values for chemical substances and physical agents & biological exposure indices. Cincinnati, OH.
Alstead, S. (1936). Acid ammonium phosphate as a urinary acidifier. Edinb Med J 43: 292–302.29647006
Aoyama, M. (1975). Effect of anti-flame treating agents on the skin. Nagoya Med J 20: 11–19.
ATSDR (Agency for Toxic Substances and Disease Registry). (2004). Toxicological profile for ammonia [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. http://www.atsdr.cdc.gov/toxprofiles/tp.asp?id=11&tid=2
ATSDR (Agency for Toxic Substances and Disease Registry). (2020). Toxic substances portal: Toxicological profiles. Atlanta, GA. https://www.atsdr.cdc.gov/toxprofiledocs/index.html
Becker, TS; Schuhmacher, G; Stich, R; Eyer, F; Knuefermann, P. (2018). [Life-threatening metabolic acidosis after ingestion of fire extinguisher powder]. Anaesthesist 67: 674–678. 10.1007/s00101-018-0477-7 30178118
Bhat, MR; Ramaswamy, C. (1993). Effect of ammonia, urea and diammonium phosphate (DAP) on lung functions in fertilizer plant workers. Indian J Physiol Pharmacol 37: 221–224.8276500
Blumenthal, R; Hänert-Van der Zee, B. (2018). A fire extinguisher death: the Macklin effect. Am J Forensic Med Pathol 39: 103–105. 10.1097/PAF.0000000000000374 29278538
CalEPA (California Environmental Protection Agency). (2019). OEHHA chemical database. Sacramento, CA: Office of Environmental Health Hazard Assessment. Retrieved from https://oehha.ca.gov/chemicals
CalEPA (California Environmental Protection Agency). (2020). Consolidated table of OEHHA/ARB approved risk assessment health values (May 8, 2018 ed.). Sacramento, CA: California Air Resources Board. https://www.arb.ca.gov/toxics/healthval/contable.pdf
Chateaubodeau, GD; Guerin, M; Guerin, B. (1974). Studies on anionic transport in yeast mitochondria and promitochondria. Swelling in ammonium phosphate, glutamate, succinate and fumarate solutions. FEBS Lett 46: 184–187. 10.1016/0014-5793(74)80364-9 4608320
CIR Expert Panel (Cosmetic Ingredient Review Expert Panel). (2016). Safety assessment of phosphoric acid and simple salts as used in cosmetics. Cosmetic Ingredient Review. https://www.cir-safety.org/supplementaldoc/safety-assessment-phosphoric-acid-and-simple-salts-used-cosmetics-0
Clawson, AJ; Armstrong, WD. (1981). Ammonium polyphosphate as a source of phosphorus and nonprotein nitrogen for monogastrics. J Anim Sci 52: 1–7. 10.2527/jas1981.5211 7240028
Colenbrander, VF; Muller, LD; Wasson, JA; Cunningham, MD. (1971). Effects of added urea and ammonium polyphosphate to corn stover silages on animal performance. J Anim Sci 33: 1091–1096. 10.2527/jas1971.3351091x 5119973
Damron, BL; Flunker, LK. (1990). Supplementation of broiler drinking water with liquid ammonium polyphosphate. Br Poult Sci 32: 377–382. 10.1080/00071669108417362
DOE (U.S. Department of Energy). (2018). Table 2: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. https://edms.energy.gov/pac/docs/Revision_29A_Table2.pdf
Doyon, S; McGrath, JM. (2003). Hyperphosphatemia and cardiac arrest following inhalation of a dry chemical fire extinguisher [Abstract]. J Toxicol Clin Toxicol 41: 609–640.
ECHA (European Chemicals Agency). (2001a). Diammonium hydrogenorthophosphate. Genetic toxicity: in vitro. 002 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/15555/7/7/2/?documentUUID=847e6f2a-8313-49ef-a678-1f24472485f5
ECHA (European Chemicals Agency). (2001b). Diammonium hydrogenorthophosphate. Genetic toxicity: in vitro. 003 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/15555/7/7/2/?documentUUID=6dcb7602-ce92-40ef-99fa-9c025a36d475
ECHA (European Chemicals Agency). (2002). Diammonium hydrogenorthophosphate. Repeated dose toxicity: oral. 001 Key | Experimental result. https://echa.europa.eu/en/registration-dossier/-/registered-dossier/15555/7/6/2
ECHA (European Chemicals Agency). (2010a). Ammonium dihydrogenorthophosphate. Genetic toxicity: in vitro. 003 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/15548/7/7/2/?documentUUID=0c244a40-682c-46c0-9816-e842566cfee5
ECHA (European Chemicals Agency). (2010b). Ammonium dihydrogenorthophosphate. Skin sensitisation: in vivo (LLNA). 001 Key | Experimental result. Helsinki, Finland. https://echa.europa.eu/lv/registration-dossier/-/registered-dossier/15548/7/5/2
ECHA (European Chemicals Agency). (2019a). Registration dossier: Ammonium dihydrogenorthophosphate. https://echa.europa.eu/registration-dossier/-/registered-dossier/15548
ECHA (European Chemicals Agency). (2019b). Registration dossier: Diammonium hydrogenorthophosphate. https://echa.europa.eu/registration-dossier/-/registered-dossier/15555
ECHA (European Chemicals Agency). (2019c). Registration dossier: Polyphosphoric acids, ammonium salts. https://echa.europa.eu/registration-dossier/-/registered-dossier/11698
Fishwick, G; Hemingway, RG. (1974). Proceedings: Utilization of dietary ammonium polyphosphate by growing wether lambs [Abstract]. Proc Nutr Soc 33: 46A–47A.
Gard, DR. (2005). Phosphoric acids and phosphates. In Kirk-Othmer encyclopedia of chemical technology. John Wiley & Sons, Inc. https://onlinelibrary.wiley.com/doi/10.1002/0471238961.1608151907011804.a01.pub2
Hemingway, RG; Fishwick, G. (1975). Ammonium polyphosphate in the drinking-water as a source of phosphorus for growing sheep [Abstract]. Proc Nutr Soc 34: 78A–79A.
Hendriks, HS; Meijer, M; Muilwijk, M; van den Berg, M; Westerink, RHS. (2014). A comparison of the in vitro cyto- and neurotoxicity of brominated and halogen-free flame retardants: Prioritization in search for safe(r) alternatives. Arch Toxicol 88: 857–869. 10.1007/s00204-013-1187-1 24395120
Hommes, FA; Mastebroek-Helder, DJ; Molenaar, I. (1975). The effect of vitamin E deficiency on permeability of mitochondria for phosphate. Nutr Metab 19: 263–267.1232597
IARC (International Agency for Research on Cancer). (2019). Agents classified by the IARC monographs. Lyon, France. http://monographs.iarc.fr/ENG/Classification/List_of_Classifications.pdf
ICL (ICL Industrial Products). (2006). Material safety data sheet: Phos-Chek® fire retardant grades D-75F and D-75R. ICL Performance Products LP. https://studylib.net/doc/10996441/material-safety-data-sheet
ICL (ICL Industrial Products). (2015). Safety data sheet: Phos-Chek® fire retardant grades 259-F, 259-R, 259-W. ICL Performance Products LP. https://msdsdigital.com/phos-chek®fire-retardant-grades-259-f-259-r-259-w-msds
IPCS (International Programme on Chemical Safety). (2020). INCHEM: Chemical safety information from intergovernmental organizations [Database]. Geneva, Switzerland: World Health Organization, Canadian Centre for Occupational Health and Safety. Inter-Organization Programme for the Sound Management of Chemicals. Retrieved from http://www.inchem.org/
Ivy, RE; Sullivan, TW; Goldner, WJ; Graff, CR; Peo, ER, Jr. (1974). Availability and toxicity of fertilizer phosphates in the rat [Abstract]. Poult Sci 53: 1939.
Jensen, LS; Edwards, HM. (1980). Availability of phosphorus from ammonium polyphosphate for growing chickens. Poult Sci 59: 1280–1283. 10.3382/ps.0591280 7402994
Koolivand, A; Yari, M; Khalaji, S; Jonker, A. (2019). Feeding di-ammonium phosphate as a phosphorous source in finishing lambs reduced excretion of phosphorus in feces without detrimental effects on animal performance. Asian-Australas J Anim Sci 32: 527–532. 10.5713/ajas.17.0591 29381906
Kornegay, ET. (1972). Supplementation of lysine, ammonium polyphosphate and urea in diets for growing-finishing pigs. J Anim Sci 34: 55–63. 10.2527/jas1972.34155x 5062064
Lee, DH; Choi, YH; Lee, DH. (2016). Delayed aspiration pneumonia and systemic toxicity in patient who inhaled dry powder of fire extinguisher. Hong Kong Journal of Emergency Medicine 23: 234–237. 10.1177/102490791602300405
Lin, CJ; Chen, HH; Chang, KS; Hsu, CY; Chen, YC; Wu, CJ. (2009). Metabolic disarray after fire extinguisher powder ingestion. Kidney Int 75: 993–994. 10.1038/ki.2008.668 19367312
Lundberg, P. (1975). ATP- and phosphate-induced configurational changes of submitochondrial particles. Biochim Biophys Acta 376: 458–469. 10.1016/0005-2728(75)90167-X 1168498
McClure, FJ. (1964). Cariostatic effect of phosphates. Science 144: 1337–1338. 10.1126/science.144.3624.1337 14171523
Monsanto (Monsanto Company). (1992). Initial submission: Letter from Monsanto Co to USEPA regarding Phos-Chek 295F fire retardant premix with attachments and cover letter dated 08/10/1992. (EPA/OTS; Doc #88-920007704).
NIOSH (National Institute for Occupational Safety and Health). (2018). NIOSH pocket guide to chemical hazards. Index of chemical abstracts service registry numbers (CAS No.). Atlanta, GA. http://www.cdc.gov/niosh/npg/npgdcas.html
NLM (National Library of Medicine). (2019a). ChemID plus advanced. Ammonium dihydrogen phosphate, RN: 7722-76-1. Available online at https://chem.nlm.nih.gov/chemidplus/rn/7722-76-1
NLM (National Library of Medicine). (2019b). ChemID plus advanced. Ammonium phosphate [NF], RN: 7783-28-0. Available online at https://chem.nlm.nih.gov/chemidplus/rn/778328-0
NLM (National Library of Medicine). (2019c). ChemID plus advanced. Polyphosphoric acids, ammonium salts, RN: 68333-79-9. Available online at https://chem.nlm.nih.gov/chemidplus/rn/68333-79-9
NRC (National Research Council). (2000). Toxicological risks of selected flame-retardant chemicals. Washington, DC: National Academy Press. 10.17226/9841
NTP (National Toxicology Program). (2016). 14th Report on carcinogens. Research Triangle Park, NC. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html
OECD (Organisation for Economic Co-operation and Development). (1996). Test no. 422: Combined repeated dose toxicity study with the reproduction/developmental toxicity screening test: 1996 version. In OECD guidelines for the testing of chemicals, Section 4: Health effects. Paris, France. 10.1787/9789264070981-en
OECD (Organisation for Economic Co-operation and Development). (2007a). SIDS dossier: CAS No. 7722-76-1. Monoammonium phosphate [OECD SIDS]. https://hpvchemicals.oecd.org/UI/handler.axd?id=87572146-b81f-4bc5-9e67-4427c64b1901
OECD (Organisation for Economic Co-operation and Development). (2007b). SIDS dossier: CAS No. 7783-28-0. Diammonium phosphate [OECD SIDS]. https://hpvchemicals.oecd.org/UI/handler.axd?id=87572146-b81f-4bc5-9e67-4427c64b1901
OECD (Organisation for Economic Co-operation and Development). (2007c). SIDS dossier: CAS No. 8011-76-5. Triple superphospate [OECD SIDS]. https://hpvchemicals.oecd.org/UI/handler.axd?id=87572146-b81f-4bc5-9e67-4427c64b1901
OECD (Organisation for Economic Co-operation and Development). (2007d). SIDS dossier: CAS No. 68333-79-9. Ammonium polyphosphate [OECD SIDS]. https://hpvchemicals.oecd.org/UI/handler.axd?id=87572146-b81f-4bc5-9e67-4427c64b1901
OECD (Organisation for Economic Co-operation and Development). (2007e). SIDS initial assessment profile for SIAM 24: Monoammonium phosphate (MAP), diammonium phosphate (DAP), ammonium polyphosphate (APP), single superphosphate (SSP), triple superphosphate (TSP). CAS Nos. 7722-76-1, 7783-28-0, 68333-79-9, 8011-76-5, 65996-95-4 [OECD SIDS]. https://hpvchemicals.oecd.org/UI/handler.axd?id=f601b74f-c7d7-4400-ac9a-3987145c3302
OECD (Organisation for Economic Co-operation and Development). (2007f). SIDS initial assessment report for SIAM 24 [OECD SIDS]. https://hpvchemicals.oecd.org/UI/handler.axd?id=87572146-b81f-4bc5-9e67-4427c64b1901
OECD (Organisation for Economic Co-operation and Development). (2021). Test no. 405: Acute eye irritation/corrosion. In OECD guidelines for the testing of chemicals. Paris, France: OECD Publishing. 10.1787/9789264185333-en
OSHA (Occupational Safety & Health Administration). (2018a). Air contaminants: Occupational safety and health standards for shipyard employment, Subpart Z, toxic and hazardous substances. (OSHA Standard 1915.1000). Washington, DC: U.S. Department of Labor. https://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10286
OSHA (Occupational Safety & Health Administration). (2018b). Table Z-1: Limits for air contaminants. Occupational safety and health standards, Subpart Z, toxic and hazardous substances. Available online at http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=9992 (accessed June 6, 2019).
OSHA (Occupational Safety & Health Administration). (2020). Safety and health regulations for construction: Occupational health and environmental controls: Gases, vapors, fumes, dusts, and mists: Appendix A. Available online at http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10629
Ruhe, RL; Ehrenberg, R. (1985). Health hazard evaluation report: HETA-84-172-1573 - Philadelphia Limerick Power Plant, Pottstown, Pennsylvania. (NIOSH/00153392; HETA-84-172-1573). Cincinnati, OH: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/hhe/reports/pdfs/84-172-1573.pdf
Scott, JM. (1931). Ammonium phosphate as a urinary acidifier. Can Med Assoc J 25: 666–667.20318530
Senthilkumaran, S; Meenakshisundaram, R; Balamurgan, N; SathyaPrabhu, K; Karthikeyan, V; Thirumalaikolundusubramanian, P. (2012). Fire extinguisher: an imminent threat or an eminent danger? Am J Emerg Med 30: 515.e513–515.e515. 10.1016/j.ajem.2011.01.018
Sitaramam, V; Rao, NM. (1992). Membrane instability in respiring mitochondria: role of phosphate. Indian J Biochem Biophys 29: 103–114.1398702
Stoner, CD; Sirak, HD. (1971). Swelling and contraction of mitochondria suspended in ammonium phosphate [Abstract]. Fed Proc 30: 1237.
Stoner, CD; Sirak, HD. (1978). Swelling and contraction of heart mitochondria suspended in ammonium phosphate. J Bioenerg Biomembr 10: 75–88. 10.1007/BF00743053 556069
Struwe, FJ; Sullivan, TW. (1975). Fluorine and phosphorus relationships in diets for starting and growing finishing turkeys [Abstract]. Poult Sci 54: 1821. 10.3382/ps.0541724
Summerill, RA; Lee, KE. (1985). Phosphate excretion and reabsorption in the conscious dog. Q J Exp Physiol 70: 169–176. 10.1113/expphysiol.1985.sp002900 4011833
Tunmire, DL; Orr, DE; Tribble, LF. (1983). Ammonium polyphosphate versus dicalcium phosphate as a phosphorus supplement for growing-finishing swine. J Anim Sci 57: 632–637. 10.2527/jas1983.573632x 6630097
U.S. APHC (U.S. Army Public Health Command). (2013). Environmental health risk assessment and chemical exposure guidelines for deployed military personnel. (Technical guide 230, 2013 revision). Aberdeen Proving Ground, MD. https://phc.amedd.army.mil/PHC%20Resource%20Library/TG230-DeploymentEHRA-and-MEGs-2013-Revision.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2002). A review of the reference dose and reference concentration processes. (EPA/630/P-02/002F). Washington, DC. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2005). Guidelines for carcinogen risk assessment [EPA Report]. (EPA/630/P-03/001F). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3-25-05.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2011a). Health effects assessment summary tables (HEAST) for superfund. Available online at https://epa-heast.ornl.gov/heast.php
U.S. EPA (U.S. Environmental Protection Agency). (2011b). Recommended use of body weight 3/4 as the default method in derivation of the oral reference dose. (EPA/100/R-11/0001). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/recommended-use-of-bw34.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2012). Benchmark dose technical guidance. (EPA/100/R-12/001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/benchmark-dose-technical-guidance
U.S. EPA (U.S. Environmental Protection Agency). (2018). 2018 Edition of the drinking water standards and health advisories [EPA Report]. (EPA/822/F-18/001). Washington, DC: U.S. Environmental Protection Agency, Office of Water. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2020). Integrated risk information system. IRIS assessments [Database]. Washington, DC. Retrieved from http://www.epa.gov/iris/
Weiner, ML; Salminen, WF; Larson, PR; Barter, RA; Kranetz, JL; Simon, GS. (2001). Toxicological review of inorganic phosphates [Review]. Food Chem Toxicol 39: 759–786. 10.1016/S0278-6915(01)00028-X 11434984
WHO (World Health Organization). (1982). Phosphoric acid and phosphate salts. In Toxicological evaluation of certain food additives and contaminants. (WHO Food Additive Series 17). Geneva, Switzerland: International Programme on Chemical Safety.