# APPENDIX C BENCHMARK DOSE MODELING RESULTS

## MODELING PROCEDURE FOR DICHOTOMOUS DATA

The benchmark dose (BMD) modeling of dichotomous data is conducted with the U.S. Environmental Protection Agency (U.S. EPA) Benchmark Dose Software (BMDS; Version 3.1.1 was used for this document). For these data, the Gamma, Logistic, Log-Logistic, Probit, Log-Probit, Hill, Multistage, and Weibull dichotomous models available within the software are fit using a benchmark response (BMR) of 10% extra risk. Alternative BMRs may also be used where appropriate, as outlined in the U.S. EPA’s Benchmark Dose Technical Guidance (U.S. EPA, 2012). In general, the BMR should be near the low end of the observable range of increased risk in the study. BMRs that are too low can result in widely disparate benchmark dose lower confidence limit (BMDL) estimates from different models (high model dependence). Adequacy of model fit is judged based on the χ^2^ goodness-of-fit p-value (p > 0.1), magnitude of scaled residuals (absolute value <2.0), and visual inspection of the model fit. Among all models providing adequate fit, the BMDL from the model with the lowest Akaike’s information criterion (AIC) is selected as a potential point of departure (POD), if the BMDLs are sufficiently close (less than approximately threefold); if the BMDLs are not sufficiently close (greater than approximately threefold), model dependence is indicated, and the model with the lowest reliable BMDL is selected.

### Dropping the High Dose

In the absence of a mechanistic understanding of the biological response to a toxic agent, data from exposures much higher than the study’s lowest-observed-adverse-effect level (LOAEL) do not provide reliable information regarding the shape of the response at low doses. Such exposures, however, can have a strong effect on the shape of the fitted model in the low-dose region of the dose-response curve. Thus, if lack of fit is due to characteristics of the dose-response data for high doses, then the Benchmark Dose Technical Guidance document allows for data to be adjusted by eliminating the high-dose group (U.S. EPA, 2012). Because the focus of BMD analysis is on the low-dose regions of the response curve, elimination of the high-dose group may be reasonable for certain datasets.

### Submucosal Inflammation of the Stomach in Rats Exposed to DAP by Gavage for 35 Days [Huntingdon (2002) as cited in OECD (2007b) and ECHA (2002)]

The procedure outlined above for dichotomous data was applied to the data for submucosal inflammation of the stomach in Sprague Dawley rats (both sexes combined) exposed to DAP via gavage for 35 days (see Table B-2). Table C-1 summarizes the BMD modeling results. With all dose groups included, the Log-Logistic, Log-Probit, and Hill models provided adequate fit (p > 0.1); however, the BMDs for these models varied widely (3 orders of magnitude); and the BMDLs for both the Log-Probit and Hill models were calculated as 0, while the Log-Logistic model yielded a BMDL estimate that was more than 12-fold lower than the lowest experimental dose. Because of these limitations when modeling the full dataset, and since the incidence at the high dose was lower than at the mid dose (750 mg DAP/kg-day), BMD modeling was then performed with the high-dose group removed from analysis, as consistent with Benchmark Dose Technical Guidance (U.S. EPA, 2012). Without the highest dose group, additional model fit was obtained, with the Gamma, Log-Logistic, Multistage (2-degree and 1-degree), and Weibull models providing adequate fits to the data. Three separate, adequately fitting models (Gamma, Multistage [2-degree and 1-degree], and Weibull) also estimated the same BMD_10_ and BMDL_10_ values of 44.3 and 27.7 mg/kg-day, respectively, with the Multistage and Weibull models having the lowest AICs. Based on these more acceptable fits to the data after removing the high dose, a BMDL_10_ of 27.7 mg/kg-day was identified for increased incidence of stomach submucosal inflammation (minimal/slight) in rats.

Table C-1 BMD Modeling Results for Submucosal Inflammation of the Stomach in Sprague Dawley Rats (Males and Females Combined) Administered DAP (CASRN 7783-28-0) via Gavage for 35 Days^a^

Model | df | χ^2^ | χ^2^ Goodness-of-Fit p-Value^b^ | Scaled Residual at Dose Nearest (below) BMD | Scaled Residual at Dose Nearest (above) BMD^c^ | AIC | BMD_10_ (mg DAP/kg-d) | BMDL_10_ (mg DAP/kg-d)
Full dataset
Gamma^d^ | 2 | 9.03 | 0.01 | −0.0004 | 1.63 | 48.97 | 83.35 | 56.95
Log-Logistic^e^ | 3 | 3.80 | 0.28 | −0.0004 | 0.56 | 42.69 | 39.48 | 19.94
Multistage (3-degree)^f^ | 2 | 9.03 | 0.01 | −0.0004 | 1.63 | 48.97 | 83.35 | 56.95
Multistage (2-degree)^f^ | 3 | 9.03 | 0.03 | −0.0004 | 1.63 | 46.97 | 83.35 | 56.95
Multistage (1-degree)^f^ | 2 | 9.03 | 0.01 | −0.0004 | 1.63 | 48.97 | 83.35 | 56.95
Weibull^d^ | 2 | 9.03 | 0.01 | −0.007 | 1.63 | 48.97 | 83.36 | 56.95
Dichotomous Hill | 1 | 0.95 | 0.33 | −0.0004 | −4.08 × 10^−5^ | 44.30 | 188.19 | 0.00
Logistic | 2 | 9.33 | 0.01 | −1.91 | 1.03 | 53.27 | 238.16 | 154.31
Log-Probit^e^ | 2 | 1.62 | 0.44 | −0.0004 | −0.39 | 43.04 | 0.17 | 0.00
Probit | 2 | 9.36 | 0.01 | −1.89 | 1.06 | 53.27 | 238.33 | 161.44
Highest dose dropped
Gamma^d^ | 1 | 0.18 | 0.67 | −0.0004 | 0.33 | 28.05 | 44.30 | 27.70
Log-Logistic^e^ | 1 | 1.52 × 10^−7^ | 0.9997 | −0.0004 | 1.72 × 10^−7^ | 27.87 | 43.82 | 10.90
Multistage (1-degree)^f^ * | 2 | 0.18 | 0.91 | −0.0004 | 0.33 | 26.05 | 44.30 | 27.70
Multistage (2-degree)^f^ * | 2 | 0.18 | 0.91 | −0.0004 | 0.33 | 26.05 | 44.30 | 27.70
Weibull^d^ * | 2 | 0.18 | 0.91 | −0.0004 | 0.33 | 26.05 | 44.30 | 27.70
Dichotomous Hill | −1 | 1.53 × 10^−7^ | 65,535 | −0.0004 | −3.70 × 10^−6^ | 31.87 | 47.58 | 0
Logistic | 1 | 3.05 | 0.08 | −1.20 | 1.20 | 31.98 | 130.38 | 79.11
LogProbit^e^ | 0 | 1.78 × 10^−7^ | NA | −0.0004 | −2.97 × 10^−5^ | 29.87 | 46.92 | 0
Probit | 1 | 3.01 | 0.08 | −1.08 | 1.26 | 31.79 | 127.12 | 81.44

a Huntingdon (2002) as cited in OECD (2007b) and ECHA (2002).

b Values <0.10 fail to meet conventional goodness-of-fit criteria.

c Scaled residuals nearest BMDs were closest to the controls; therefore, scaled residual at nearest dose above (250 mg DAP/kg-day) were presented.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

* Best fitting model(s) identified in bold.

AIC = Akaike’s information criterion; BMD = benchmark dose; BMDL = 95% lower confidence limit on the BMD (subscripts denote BMR: i.e., 10 = dose associated with 10% extra risk); BMR = benchmark response; DAP = diammonium phosphate; df = degrees of freedom; NA = not applicable (computation failed).

Figure C-1 Fit of Multistage (1-degree) Model to Data for Submucosal Inflammation of the Stomach in Sprague Dawley Rats (Males and Females Combined) Administered DAP (CASRN 7783-28-0) via Gavage for 35 Days [Huntingdon (2002) as cited in OECD (2007b) and ECHA (2002)]