# APPENDIX B DATA TABLES

Table B-1 Comparison between Spirometry Findings in Workers at DAP (CASRN 7783-28-0) Fertilizer Plant and Controls^a^

Spirometry Parameter | Control (n = 68) | DAP Plant Workers (n = 30)
FVC (L) | 3.43 ± 0.21^b^ | 2.51 ± 0.06^*^ (−27%)^c^
FEV_1_ (L) | 2.84 ± 0.10 | 2.08 ± 0.08^*^ (−27%)
PEFR/min (L/min) | 383 ± 7.6 | 227.6 ± 18.2^*^ (−41%)

a Bhat and Ramaswamy (1993).

b Mean ± SE (specified for controls in Table II of the publication).

c Value in parentheses is % change relative to control = [(treatment mean − control mean) ÷ control mean] × 100.

* Significantly different from control by paired t-test (p < 0.01), as reported by the study authors.

DAP = diammonium phosphate; FEV_1_ = forced expiratory volume of 1 second; FVC = forced vital capacity; PEFR = peak expiratory flow rate; SE = standard error.

Table B-2 Incidence of Minimal or Slight Submucosal Inflammation of the Stomach in Rats Exposed to DAP (CASRN 7783-28-0) by Gavage for 35 Days^a^

Dose (mg DAP/kg-d) | Male (%) | Female (%) | Combined (%)
0 | 0/5 (0)^b^ | 0/5 (0) | 0/10 (0)
250 | 3/5 (60) | 2/5 (40) | 5/10^*^ (50)
750 | 4/5^*^ (80) | 4/5^*^ (80) | 8/10^*^ (80)
1,500 | 2/5 (40) | 4/5^*^ (80) | 6/10^*^ (60)

a Toxicity subgroup of Huntingdon (2002) as cited in OECD (2007b) and ECHA (2002).

b Values denote number of animals showing changes/total number of animals examined (% incidence).

* Significantly different from control by Fisher’s exact test (one-sided p < 0.05) conducted for this review.

DAP = diammonium phosphate.