# APPENDIX A SCREENING PROVISIONAL VALUES

For reasons noted in the main Provisional Peer-Reviewed Toxicity Value (PPRTV) document, it is inappropriate to derive provisional reference doses (p-RfDs) for any of the ammonium phosphate salts. However, some information is available for diammonium phosphate (DAP), which although insufficient to support derivation of a provisional toxicity value under current guidelines, may be of limited use to risk assessors. In such cases, the Center for Public Health and Environmental Assessment (CPHEA) summarizes available information in an appendix and develops a “screening value.” Appendices receive the same level of internal and external scientific peer review as the provisional reference values to ensure their appropriateness within the limitations detailed in the document. Users of screening toxicity values in an appendix to a PPRTV assessment should understand that there may be more uncertainty associated with the derivation of an appendix screening toxicity value than for a value presented in the body of the assessment. Questions or concerns about the appropriate use of screening values should be directed to CPHEA.

## DERIVATION OF SCREENING PROVISIONAL REFERENCE DOSES

As discussed in the main body of the report, the only available oral study with adequate information to derive effect levels [Huntingdon (2002) as cited in OECD (2007b) and ECHA (2002)] was unpublished and available as reported in a secondary source. However, this Good Laboratory Practice (GLP)- and Organisation for Economic Co-operation and Development (OECD) guideline-compliant study appears to have been well conducted, was peer reviewed by the European Chemicals Agency (ECHA) and OECD and provides dose-response information suitable for deriving a screening-level provisional toxicity value for DAP.

A lowest-observed-adverse-effect level (LOAEL) of 250 mg DAP/kg-day (the lowest dose tested) was identified for the study by Huntingdon (2002) as cited in OECD (2007b) and ECHA (2002) based on increased incidence of stomach submucosal inflammation in both sexes at all doses. Benchmark dose (BMD) modeling on the stomach inflammation data (see Table B-2) was completed using the U.S. Environmental Protection Agency (U.S. EPA) Benchmark Dose Software (BMDS, Version 3.1.1). Combined incidences in male and female rats (higher n vs. sex-specific) were modeled to reduce uncertainty around benchmark dose lower confidence limit (BMDL) estimates, as consistent with Agency guidance.^4^ Results of BMD modeling are summarized in Appendix C. Despite a flat dose-response, model results yielded satisfactory fit of the data for several models after the high dose was dropped, with BMD_10_ and BMDL_10_ estimates of 44.3 and 27.7 mg DAP/kg-day, respectively. A BMDL_10_ of 27.7 mg/kg-day was therefore selected as the point of departure (POD). Confidence in this value is increased by the recognition that it is virtually identical to that derived from an alternative approach using the animal LOAEL of 250 mg/kg-day from the critical study as POD and applying a LOAEL-to-no-observed-adverse-effect level (NOAEL) uncertainty factor (UF_L_) of 10.

### Derivation of Screening Subchronic Provisional Reference Dose

U.S. EPA endorses a hierarchy of approaches to derive human equivalent doses (HEDs) from data from laboratory animal species, with the preferred approach being physiologically based toxicokinetic modeling. Another approach may include using chemical-specific information, including what is known about the toxicokinetics and toxicodynamics of the chemical, to derive chemical-specific adjustments. In the absence of chemical-specific information to derive human equivalent oral exposures, U.S. EPA endorses body-weight scaling to the 3/4 power (i.e., BW^3/4^) as a default to extrapolate toxicologically equivalent doses of orally administered agents from all laboratory animals to humans for the purpose of deriving an oral reference dose (RfD) under certain exposure conditions (U.S. EPA, 2011b). More specifically, the use of BW^3/4^ scaling for deriving an RfD is recommended when the observed effects are associated with the parent compound or a stable metabolite but not typically for portal-of-entry effects. Because the selected critical effect is stomach submucosal inflammation (portal-of-entry effect) in rats, the use of BW^3/4^ scaling is not appropriate in this case.

A screening subchronic p-RfD of 9 × 10^−2^ mg DAP/kg-day is derived by applying a composite uncertainty factor (UF_C_) of 300 (reflecting an interspecies uncertainty factor [UF_A_] of 10, an intraspecies uncertainty factor [UF_H_] of 10, and a database uncertainty factor [UF_D_] of 3 to the selected POD of 27.7 mg DAP/kg-day (BMDL_10_) for submucosal inflammation in stomach of rats exposed to DAP, as follows:

Screening Subchronic p-RfD = BMDL_10_ ÷ UF_C_ = 27.7 mg DAP/kg-day ÷ 300 = 9 × 10^− 2^ mg DAP/kg-day

Table A-1 summarizes the uncertainty factors for the screening subchronic p-RfD for DAP. The screening subchronic p-RfD for DAP is expected to be protective for monoammonium phosphate (MAP) also, given the physicochemical similarities between DAP and MAP (e.g., MAP possesses one less ammonium ion). However, it should not be applied to the risk assessment of ammonium polyphosphate, which is anticipated to have a much wider range of potential and variable structures, physicochemical properties, and ammonium content (see Table 1), and for which relevant toxicity data are not available to derive a p-RfD.

Table A-1 Uncertainty Factors for the Screening Subchronic p-RfD for DAP (CASRN 7783-28-0) and MAP (CASRN 7722-76-1)

UF | Value | Justification
UF_A_ | 10 | A UF_A_ of 10 is applied to account for uncertainty in extrapolating from animals to humans for oral portal-of-entry effects of DAP.
UF_D_ | 3 | A UF_D_ of 3 is applied to account for deficiencies and uncertainties in the database. The oral database for ammonium phosphate salts includes secondary, peer-reviewed accounts of acute lethality studies in rats, a well-conducted, GLP- and OECD guideline-compliant 35-d combined repeated-dose and 28/53 (M/F)-d reproductive/developmental screening toxicity study in rats (critical study), a chronic study in rabbits evaluating only parathyroid gland weight, and negative genotoxicity studies. In the critical study, no reproductive, developmental, or neurobehavioral effects were observed up to the highest dose tested (1,500 mg/kg-d), which exceeded the limit dose, in either the toxicity or reproductive arm of the critical study. Local toxicity at the site of administration is considered the critical effect with DAP. Therefore, the UF_D_ can be reduced from 10 to 3.
UF_H_ | 10 | A UF_H_ of 10 is applied to account for human variability in susceptibility to portal-of-entry effects from oral exposure to DAP.
UF_L_ | 1 | A UF_L_ of 1 is applied for LOAEL-to-NOAEL extrapolation because the POD is a BMDL_10_.
UF_S_ | 1 | A UF_S_ of 1 is applied because the study length (>35 d) is of an appropriate subchronic duration.
UF_C_ | 300 | Composite UF = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_.

BMD = benchmark dose; BMDL = 95% lower confidence limit on the BMD (subscripts denote BMR: i.e., 10 = dose associated with 10% extra risk); BMR = benchmark response; DAP = diammonium phosphate; F = female(s); GLP = Good Laboratory Practice; LOAEL = lowest-observed-adverse-effect level; M = male(s); MAP = monoammonium phosphate; NOAEL = no-observed-adverse-effect level; OECD = Organisation for Economic Co-operation and Development; POD = point of departure; p-RfD = provisional reference dose; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

Because the determinant of the local toxicity (irritation) of DAP and MAP is expected to be the ammonium ion, the toxicity of these compounds is directly related to the relative molecular weight contribution from ammonium. Therefore, the screening subchronic p-RfD derived above for DAP is applicable to MAP following application of a molecular-weight adjustment and appropriate stoichiometric calculations.

### Derivation of Screening Chronic Provisional Reference Dose

There are no adequate chronic-duration oral studies available for ammonium phosphate salts. The longest available study that could serve as the basis for toxicity assessment is the OECD 422 guideline study (combined repeated-dose toxicity study with reproductive/developmental screening test [Huntingdon (2002) as cited in OECD (2007b) and ECHA (2002)]). The systemic toxicity subgroup in that study was only treated for 35 days, which is not of adequate study duration for deriving a screening chronic p-RfD. In the reproductive component of the study, parental females were treated up to 53 days, which is of sufficient duration to derive a chronic value. In this case, however, stomach histopathology was only assessed in the systemic toxicity subgroup, which was treated for only 35 days. Because the critical effect was not assessed in the reproductive toxicity subgroup, it is unclear if the reproductive NOAEL of 1,500 mg/kg-day would be protective of stomach lesions caused by exposure to ammonium phosphate salts in a chronic setting. Therefore, derivation of a screening chronic p-RfD is not supported.

4 Section 2.1.6 (Combining Data for a BMD Calculation) of Benchmark Dose Technical Guidance (U.S. EPA, 2012).