# 3 DERIVATION OF PROVISIONAL VALUES

## 3.1 DERIVATION OF PROVISIONAL REFERENCE DOSES

No subchronic or chronic studies have been located regarding the toxicity of 3,4-TDA to humans or animals via oral administration. Potentially relevant toxicity data for 3,4-TDA are limited to a 5-day gavage study that reported perforating duodenal ulcers in rats following exposure to 1,000 mg/kg-day (Selye, 1973). Additionally, gavage exposure studies evaluating TDA mixtures containing the 3,4-TDA isomer (approximately 50−60% 3,4-TDA) showed some evidence of potential R/D effects in rats at 250 mg/kg-day following premating through PND 4 and in rats and rabbits at ≥100 mg/kg-day following gestational exposure, primarily at doses associated with potential maternal toxicity (BASF, 2010; Becci et al., 1983). The scope and design of these studies are inadequate to support the derivation of a subchronic or chronic provisional reference dose (p-RfD) for 3,4-TDA using chemical-specific data. Instead, screening p-RfDs are derived in Appendix A using an alternative, read-across approach. Based on the overall analogue approach presented in Appendix A, 2,5-toluenediamine was selected as the most appropriate analogue for 3,4-TDA for deriving a screening subchronic and chronic p-RfD (see Table 6).

## 3.2 DERIVATION OF PROVISIONAL REFERENCE CONCENTRATION

The absence of relevant inhalation data precludes derivation of provisional reference concentrations (p-RfCs) for 3,4-TDA directly. An alternative read-across approach was attempted, but screening p-RfCs could not be derived due to a lack of inhalation toxicity values for analogues identified (see Appendix A).

## 3.3 SUMMARY OF NONCANCER PROVISIONAL REFERENCE VALUES

The noncancer provisional reference values for 3,4-TDA are summarized in Table 6.

Table 6 Summary of Noncancer Reference Values for 3,4-Toluenediamine (CASRN 496-72-0)

Toxicity Type (units) | Species/Sex | Critical Effect | p-Reference Value | POD Method | POD | UF_C_ | Principal Study
Screening subchronic p-RfD (mg/kg-d) | Rat/F | Increased serum AST | 1 × 10^−3^ | NOAEL (HED) | 0.32 (based on analogue POD) | 300 | Hill (1997) as cited in SCCP (2007) and reported by U.S. EPA (2013)
Screening chronic p-RfD (mg/kg-d) | Rat/F | Increased serum AST | 1 × 10^−4^ | NOAEL (HED) | 0.32 (based on analogue POD) | 3,000 | Hill (1997) as cited in SCCP (2007) and reported by U.S. EPA (2013)
Subchronic p-RfC (mg/m^3^) | NDr
Chronic p-RfC (mg/m^3^) | NDr

AST = aspartate aminotransferase; F = female(s); HED = human equivalent dose; NDr = not determined; NOAEL = no-observed-adverse-effect level; POD = point of departure; p-RfC = provisional reference concentration; p-RfD = provisional reference dose; UF_C_ = composite uncertainty factor.

## 3.4 CANCER WEIGHT-OF-EVIDENCE DESCRIPTOR

Under the U.S. EPA Cancer Guidelines (U.S. EPA, 2005a), there is “Inadequate Information to Assess the Carcinogenic Potential” of 3,4-TDA (see Table 7). No relevant studies are available in humans or animals. Within the current U.S. EPA Cancer Guidelines (U.S. EPA, 2005a), there is no standard methodology to support the identification of a weight-of-evidence (WOE) descriptor and derivation of provisional cancer risk estimates for data-poor chemicals using an analogue approach. In the absence of an established framework, a screening evaluation of potential carcinogenicity is provided using the methodology described in Appendix B. This evaluation determined that there was a concern for potential carcinogenicity of 3,4-TDA (see Appendix C).

Table 7 Cancer WOE Descriptor for 3,4-Toluenediamine (CASRN 496-72-0)

Possible WOE Descriptor | Designation | Route of Entry (oral, inhalation, or both) | Comments
“Carcinogenic to Humans” | NS | NA | There are no human carcinogenicity data identified to support this descriptor.
“Likely to Be Carcinogenic to Humans” | NS | NA | There are no animal carcinogenicity studies identified to support this descriptor.
“Suggestive Evidence of Carcinogenic Potential” | NS | NA | There are no animal carcinogenicity studies identified to support this descriptor.
“Inadequate Information to Assess Carcinogenic Potential” | Selected | Both | This descriptor is selected due to the lack of adequate, chemical-specific data in humans or animals to evaluate the carcinogenic potential of 3,4-TDA.
“Not Likely to Be Carcinogenic to Humans” | NS | NA | No evidence of noncarcinogenicity is available.

NA = not applicable; NS = not selected; TDA = toluenediamine; WOE = weight of evidence.

## 3.5 DERIVATION OF PROVISIONAL CANCER RISK ESTIMATES

The absence of suitable data precludes development of cancer risk estimates for 3,4-TDA (see Table 8).

Table 8 Summary of Cancer Risk Estimates for 3,4-Toluenediamine (CASRN 496-72-0)

Toxicity Type (units) | Species/Sex | Tumor Type | Cancer Risk Estimate | Principal Study
p-OSF (mg/kg-d)^−1^ | NDr
p-IUR (mg/m^3^)^−1^ | NDr

NDr = not determined; p-IUR = provisional inhalation unit risk; p-OSF = provisional oral slope factor.