# 2 REVIEW OF POTENTIALLY RELEVANT DATA (NONCANCER AND CANCER)

As shown in Tables 3A and 3B, there are no potentially relevant subchronic or chronic studies or developmental or reproductive toxicity studies of 3,4-TDA in humans or animals for noncancer and cancer endpoints following oral or inhalation exposures. WHO (1987) described a small number of occupational health surveys of male workers exposed to diaminotoluene and dinitrotoluene mixtures; however, these studies are not useful for determining the effects of 3,4-TDA because they did not discuss or otherwise verify the presence of this isomer in the mixtures. The phrase “statistical significance” and term “significant,” used throughout the document, indicate a p-value of < 0.05 unless otherwise specified.

Table 3A Summary of Potentially Relevant Noncancer Data for 3,4-Toluenediamine (CASRN 496-72-0)

Category | Number of Male/Female, Strain, Species, Study Type, Reported Doses, Study Duration | Dosimetry | Critical Effects | Reference | Notes
Human
1. Oral (mg/kg-d)
ND
2. Inhalation (mg/m^3^)
ND
Animal
1. Oral (mg/kg-d)
ND
2. Inhalation (mg/m^3^)
ND

ND = no data.

Table 3B Summary of Potentially Relevant Cancer Data for 3,4-Toluenediamine (CASRN 496-72-0)

Category | Number of Male/Female, Strain, Species, Study Type, Reported Doses, Study Duration | Dosimetry | Critical Effects | Reference | Notes
Human
1. Oral (mg/kg-d)
ND
2. Inhalation (mg/m^3^)
ND
Animal
1. Oral (mg/kg-d)
ND
2. Inhalation (mg/m^3^)
ND

ND = no data.

## 2.1 HUMAN STUDIES

### 2.1.1 Oral Exposures

No human studies following oral exposure to 3,4-TDA have been identified.

### 2.1.2 Inhalation Exposures

No human studies following inhalation exposure to 3,4-TDA have been identified.

## 2.2 ANIMAL STUDIES

### 2.2.1 Oral Exposures

No animal studies following oral exposure to 3,4-TDA have been identified.

### 2.2.2 Inhalation Exposures

No animal studies following inhalation exposure to 3,4-TDA have been identified.

## 2.3 OTHER DATA (SHORT-TERM TESTS, OTHER EXAMINATIONS)

Toxicity data available for the 3,4-TDA isomer are limited to genotoxicity studies and a 5-day oral study with few endpoints. Additionally, studies evaluating TDA mixtures containing the 3,4-TDA isomer are available, including a reproductive toxicity study, two developmental toxicity studies, several acute lethality studies, and eye and skin irritation assays.

### 2.3.1 Genotoxicity

Available genotoxicity data for 3,4-TDA are summarized in Table 4. In vitro data indicate that 3,4-TDA has the potential to cause mutations in bacteria; however, evidence for mutation in mammalian cells is equivocal. In an NTP-sponsored study, 3,4-TDA was mutagenic to Salmonella typhimurium with, but not without, metabolic activation at concentrations as low as 333 µg/plate, with cytotoxicity reported at ≥3,333 µg/plate (Zeiger et al., 1988). Other assays showed mutagenicity in S. typhimurium following exposure to 3,4-TDA with (but not without) metabolic activation. The number of revertants increased, but they were not dose related and/or observed only at high concentrations (~500 µg/plate or higher) associated with >50% toxicity (Allied Chemical, 1983a, b, c, 1979a, b; Litton Bionetics, 1979a, b). 3,4-TDA was not mutagenic to S. typhimurium in studies using lower concentrations of ≤366 µg/plate (Watanabe et al., 1989; Florin et al., 1980); toxicity was not reported in either study. Marginal evidence for mutagenicity in Chinese hamster ovary (CHO) cells and L5178Y/TK± mouse lymphoma cells was reported at concentrations associated with cytotoxicity (Allied Chemical, 1983a, b; Litton Bionetics, 1980b; Allied Chemical, 1979a, b; Litton Bionetics, 1979a).

Available data indicate that 3,4-TDA has the potential to cause cell transformation in mammalian cells at concentrations that were often associated with cytotoxicity. A significant enhancement of viral-induced cell transformation was observed in primary Syrian hamster embryo (SHE) cell cultures following exposure to 3,4-TDA at concentrations ≥10 µg/mL either before or after inoculation with simian adenovirus SA7. Cell survival was generally <50% at all doses tested (Greene and Friedman, 1980). Evidence for induction of cell transformation in secondary SHE cell cultures was equivocal, with marginal increases in cell transformation observed in only two of five replicate assays. These findings were not dose related at noncytotoxic concentrations (≤10 µg/mL), and higher concentrations caused significant cytotoxicity (Greene and Friedman, 1980). Similarly, the number of transformed foci in Balb/3T3 cells exposed to 3,4-TDA was marginally increased only at the highest concentration (4 µg/mL), which produced 50% cytotoxicity (Litton Bionetics, 1980a, 1979a).

Limited data from in vivo studies indicate that intraperitoneal (i.p.) exposure to 3,4-TDA induces micronuclei (MN) formation in mouse bone marrow (Wild et al., 1980) and inhibits deoxyribonucleic acid (DNA) synthesis in mouse testes (Allied Chemical, 1983a, d; Greene et al., 1981; Allied Chemical, 1979a, b).

Table 4 Summary of 3,4-Toluenediamine (CASRN 496-72-0) Genotoxicity

Endpoint | Test System | Doses/Concentrations Tested | Results without Activation^a^ | Results with Activation^a^ | Comments | References
Genotoxicity studies in prokaryotic organisms
Mutation | Salmonella typhimurium; TA98, TA100, TA1535, TA1537, TA1538 | 0, 1,000, 1,710, 2,924, 5,000 µg/plate | − | +; TA98, TA1538; −; TA100, TA1535, TA1537 | Plate incorporation assay. The number of revertants was increased at all doses in TA98 and TA1538 by 2- to 7-fold, but a dose-response relationship was not observed. Relative survival was <50% for TA98, TA100, and TA1538 at ≥1,000 µg/plate with or without metabolic activation and for TA1535 and TA1537 at 5,000 µg/plate without metabolic activation. | Allied Chemical (1983a); Allied Chemical (1979a); Allied Chemical (1979b); Allied Chemical (1983b); Allied Chemical (1983c)
Mutation | S. typhimurium; TA98 | 0, 0.5, 5.0, 50, 500 µg/plate | Not tested | +; (rat S9 or mouse S9 pretreated with saline); −; (mouse S9 pretreated with 3,4-TDA) | Plate incorporation assay. Cells were metabolically activated with rat S9 or S9 prepared from C57Bl/6xC3H mice pretreated with physiological saline or 3,4-TDA (i.p.). The number of revertants was increased 2- to 4-fold at 500 µg/plate in samples activated with rat S9 or S9 prepared from C57Bl/6xC3H mice pretreated with physiological saline. Toxicity was not reported. | Allied Chemical (1983a); Allied Chemical (1979a); Allied Chemical (1979b); Allied Chemical (1983b); Allied Chemical (1983c)
Mutation | S. typhimurium; TA98, TA100, TA1535, TA1537, TA1538 | 0, 0.5, 1.0, 10, 100, 500, 1,000, 2,500, 5,000 µg/plate | − | +; TA98, TA1538; −; TA100, TA1535, TA1537 | Plate incorporation assay. The number of revertants was increased 6- to 20-fold in TA98 and 5- to 7-fold in TA1538 at ≥500 µg/plate. Toxicity was observed at ≥500 µg/plate. | Litton Bionetics (1979a); Litton Bionetics (1979b)
Mutation | S. typhimurium; TA 97, TA98, TA100, TA1535 | 0, 33, 100, 333, 666, 1,000, 3,333, 6,666, 10,000 µg/plate | − | +; TA97, TA98, TA100; −; TA1535 | Preincubation assay. The number of revertants was increased 7- to 20-fold in TA98 at ≥333 µg/plate (toxicity observed at ≥3,333 µg/plate) and at 2- to 4-fold in TA100 and TA97 at ≥1,000 µg/plate (toxicity observed at ≥6,666 µg/plate). | Zeiger et al. (1988)
Mutation | S. typhimurium; TA98, TA100, TA1535, TA1537 | 3 µmol/plate (366 µg/plate) | − | − | Spot test. The number of revertants was not increased by 3,4-TDA exposure. Toxicity was not reported. | Florin et al. (1980)
Mutation | S. typhimurium; TA98 | 0, 10, 30 µg/plate | − | − | Plate incorporation assay. The mutagenic potency of 3,4-TDA was not enhanced by the addition of H_2_O_2_, indicating that oxidative products are not mutagenic. Toxicity was not reported. | Watanabe et al. (1989)
Genotoxicity studies in mammalian cells in vitro
Mutation | CHO cells | Without S9: 0, 67, 100, 126, 149, 150, 158, 199, 223, 224, 250, 334, 447, 500 µg/mL; With S9: 0, 200, 250, 299, 354, 447, 500, 669, 707, 1,000 µg/mL | (+) | (+) | 3,4-TDA induced a dose-related increase in mutant frequency with or without metabolic activation in 1/4 replicate assays. The study authors note that cytotoxicity was higher without metabolic activation (no further details were provided). | Allied Chemical (1983a); Allied Chemical (1979a); Allied Chemical (1979b); Allied Chemical (1983b)
Mutation | L5178Y/TK± mouse lymphoma cells | Without S9: 0, 0.29, 4.69, 9.38, 13.8, 37.5 µg/mL; With S9: 0, 0.29, 18.8, 37.5, 50, 75, 100, 150 µg/mL | + | (+) | Mutation frequency was increased 2- to 8-fold at ≥13.8 µg/mL without metabolic activation and 2-fold at ≥18.8 µg/mL with metabolic activation. Moderate to high toxicity was observed at all concentrations. Without metabolic activation, high toxicity was observed at ≥9.38 µg/mL (93−98% growth inhibition). With metabolic activation, high toxicity was observed at 150 µg/mL. | Litton Bionetics (1980b); Litton Bionetics (1979a)
Cell transformation assay | Primary SHE cells inoculated with simian adenovirus SA7 | Exposure prior to viral inoculation: 0, 12.5, 25, 50, 100, 200 µg/mL; Exposure after viral inoculation: 0, 10, 18, 20, 32, 36, 56, 63, 100, 112, 200 µg/mL | + | Not tested | 3,4-TDA significantly (p < 0.05) enhanced viral transformation of primary SHE cells at all concentrations by 2- to 19-fold when added before or after viral inoculation. Survival was generally <50% at all doses tested, and 100% toxicity was observed at ≥100 µg/mL with exposure after viral inoculation. | Greene and Friedman (1980)
Cell transformation assay | Secondary SHE cells | 0, 2.5, 5.0, 10, 15, 20, 22, 33, 50 µg/mL | (+) | Not tested | 3,4-TDA induced cell transformation in two of five replicate assays. In positive replicates, 1−2 transformed loci were observed at noncytotoxic concentrations (≤10 µg/mL); findings were not dose related. The three negative replicates had “low activity” of positive control (BaP).; Relative survival was decreased by approximately 50% or more at ≥15 µg/mL. | Greene and Friedman (1980)
Cell transformation assay | Balb/3T3 cells | 0, 0.05, 0.5, 1, 2, 4 µg/mL | (+) | Not tested | A marginal increase in the total number of transformed foci was observed at 4 µg/mL, which produced 50% cytotoxicity. | Litton Bionetics (1980a); Litton Bionetics (1979a)
Genotoxicity studies in mammals in vivo
Bone marrow micronucleus test | NMRI mice treated with 3,4-TDA i.p.; 2 doses separated by 24 h; bone marrow isolated 6 h after second dose | 0, 122, 244, 366 mg/kg-d | + | | The percentage of micronucleated polychromatic erythrocytes in bone marrow was significantly (p ≤ 0.01) increased by 4.4−8% at ≥244 mg/kg-d, compared with controls. | Wild et al. (1980)
Testicular DNA synthesis inhibition test | C57Bl/6xC3H mice treated with 3,4-TDA i.p.; ^3^H-thymidine incorporation in testicular DNA was measured | 0, 500 mg/kg | + | | Significant decrease in radioactivity incorporated into DNA relative to controls (p < 0.01 in one replicate, p < 0.1 in a second replicate). | Allied Chemical (1983a); Allied Chemical (1979a); Allied Chemical (1979b); Allied Chemical (1983d)
Testicular DNA synthesis inhibition test | C57Bl/6xC3H mice treated with 3,4-TDA i.p.; ^3^H-thymidine incorporation in testicular DNA was measured | 0, 200, 299, 262, 300 mg/kg | + | | Significant decrease in radioactivity incorporated into DNA relative to controls at all doses (p < 0.025). No significant change in rectal temperature (changes in rectal temperature can affect testicular DNA synthesis). | Greene et al. (1981)

a + = positive result; (+) = weak positive result; − = negative result.

BaP = benzo[a]pyrene; CHO = Chinese hamster ovary; DNA = deoxyribonucleic acid; ^3^H = hydrogen-3 isotope (tritium); H_2_O_2_ = hydrogen peroxide; i.p. intraperitoneal; SHE = Syrian hamster embryo; TDA = toluenediamine.

### 2.3.2 Short-Term and Acute Toxicity Studies

Available short-term and acute toxicity studies of 3,4-TDA or TDA mixtures containing 3,4-TDA are summarized in Table 5.

Toxicity data for 3,4-TDA alone are limited to a short-term exposure study in which female Sprague Dawley rats were administered 3,4-TDA (97% purity) twice-daily via gavage in water at a dose of 500 mg/kg (1,000 mg/kg-day) (Selye, 1973). The study was terminated on the fifth day of exposure because 7/13 exposed rats had died (no further information on time of death was provided). Gross necropsy revealed that six of the dead animals had grossly observed perforated duodenal ulcers. Severe icterus (jaundice) was also reported, although further details were not provided. The study authors stated that comparable results were observed when males and females (10/sex) were similarly exposed via gavage in water, peanut oil, dimethylsulfoxide, or propylene glycol or via i.p. or subcutaneous (s.c.) injection (no further details were provided) (Selye, 1973).

Oral median lethal dose (LD_50_) values in rats for TDA mixtures containing 3,4-TDA range from 660−1,760 mg/kg (WIL Research, 1978; Air Products and Chemicals, 1976; Carpenter et al., 1974). An inhalation median lethal concentration (LC_50_) value >670 ppm was reported in rats exposed to o-TDA; the duration of exposure was not reported (Air Products and Chemicals, 1976). Exposure to concentrated o-TDA vapors was lethal after >8 hours of exposure (Carpenter et al., 1974). Dermal LD_50_ values for o-TDA in rabbits ranged from 1,120 to >5,750 mg/kg (Air Products and Chemicals, 1976; Carpenter et al., 1974). o-TDA is slightly to moderately irritating to rabbit skin, and the undiluted liquid is irritating to the rabbit eye (Air Products and Chemicals, 1976; Carpenter et al., 1974). Skin sensitization was “insignificant” in guinea pigs exposed to o-TDA (Air Products and Chemicals, 1976).

Table 5 Short-Term and Acute Toxicity Studies for 3,4-Toluenediamine (CASRN 496-72-0)

Test | Materials and Methods | Results | Conclusions | References
Exposure to 3,4-TDA alone
Short-term oral | Main experiment: Female Sprague Dawley rats (n = 13) were exposed to 3,4-TDA twice daily via gavage in water at 500 mg/kg per dose (1,000 mg/kg-d) for up to 5 d. The animals were observed for mortality, and gross necropsy was performed on the animals that died. | Main experiment: 7/13 rats died within the first 5 d; 6/7 dead rats had “macroscopically obvious” and “usually perforated” duodenal ulcers. Severe icterus was also reported. | Oral or parenteral exposure to high doses of 3,4-TDA caused perforating duodenal ulcers and icterus in rats. The study authors propose using 3,4-TDA to create an animal model of duodenal ulcers for testing of therapeutic interventions. | Selye (1973)
Short-term oral | Additional experiments: The main experiment was repeated with male and female rats (10/group) using water, peanut oil, dimethylsulfoxide, or propylene glycol as a vehicle, as well as with parenteral (i.p. or s.c.) exposure. | Additional experiments: Results following oral exposure “essentially the same as in the main experiment.” Result following parenteral exposure were “only doubtfully less efficacious.” No further details were provided. | | Selye (1973)
Exposure to TDA mixtures containing 3,4-TDA
Acute oral lethality | Rats were exposed to a mixture of 2,3- and 3,4-TDA in 4% aqueous solution by gavage at 6 doses. Study was reported in tabular form with no further details. | LD_50_ = 660 mg/kg. No further details were provided. | Rat oral LD_50_ = 660 mg/kg. | Air Products and Chemicals (1976)
Acute oral lethality | Rats were exposed to a mixture of 2,3- and 3,4-TDA. No further details were provided. | LD_50_ (95% CI) = 810 (590−1,120) mg/kg. No further details were provided. | Rat oral LD_50_ = 810 mg/kg. | Carpenter et al. (1974)
Acute oral lethality | Sprague Dawley rats (5/sex/group) were exposed to two mixtures containing 2,3-, 2,4-, and 3,4-TDA and 4,4-methylenedianiline at doses of 0, 310, 630, or 1,250 mg/kg via gavage in corn oil. One formulation contained 17.9% (wt) 3,4-TDA; the other was a similar formulation, but exact percentages were not “precisely known.” The animals were observed hourly for the first 6 h for signs of toxicity, and subsequently for 14 d for mortality. Gross necropsies were performed. | Most deaths occurred between 1 and 3 d postexposure. Surviving animals exhibited shallow respiration, depression, depressed righting and placement reflexes, excessive salivation, unkempt coats, piloerection, and yellowish-orange urine and mucoid diarrhea stains. All survivors were observed to be emaciated between the fourth and eighth day postexposure. Necropsies of decedents indicated congested lungs, adrenals, and kidneys; mottled livers; irritated GI tracts and peritoneal walls; and fluid-filled stomachs. Necropsies of survivors were unremarkable. | LD_50_ = 1,100−1,760 mg/kg in male rats.; LD_50_ = 1,080−1,220 mg/kg in female rats. | WIL Research (1978)
Acute inhalation lethality | Rats were exposed to a mixture of 2,3- and 3,4-TDA. Study was reported in tabular form with no further details. | LC_50_ >670 ppm. No further details were provided. | Rat inhalation LC_50_ >670 ppm. | Air Products and Chemicals (1976)
Acute inhalation lethality | Rats were exposed to the concentrated vapors of a mixture of 2,3- and 3,4-TDA. No further details were provided. | Maximum time producing no deaths was 8 h. No further details were provided. | Exposure to the concentrated vapors of a TDA mixture is lethal after >8 h of exposure. | Carpenter et al. (1974)
Acute dermal lethality | Rabbits were exposed dermally (abraded and nonabraded skin) to a mixture of 2,3- and 3,4-TDA in a 60% aqueous paste for 24 h and observed for 14 d. Study was reported in tabular form with no further details. | LD_50_ >5,750 mg/kg. No further details were provided. | Dermal LD_50_ >5,750 mg/kg. | Air Products and Chemicals (1976)
Acute dermal lethality | Rabbits were exposed to a mixture of 2,3- and 3,4-TDA on shaved backs for 24 h. No details regarding concentration or occlusion were provided. | LD_50_ (95% CI) = 1,120 (620−2,040) mg/kg. No further details were provided. | Dermal LD_50_ = 1,120 mg/kg. | Carpenter et al. (1974)
Acute dermal irritation | Rabbits were exposed to a mixture of 2,3- and 3,4-TDA on the uncovered skin of the belly. No details regarding concentration or duration of exposure were provided. | Irritation score was 5/10. | A mixture of TDA isomers is moderately irritating to the skin of rabbits. | Carpenter et al. (1974)
Skin sensitization | Guinea pigs were exposed to a mixture of 2,3- and 3,4-TDA. The study was reported in tabular form with no further details. | “Insignificant” sensitization. | A mixture of TDA isomers is not a skin sensitizer in guinea pigs. | Air Products and Chemicals (1976)
Eye irritation | Rabbits were exposed to a mixture of 2,3- and 3,4-TDA in 5% aqueous solution in eye. The study was reported in tabular form with no further details. | No irritation after 72 h. | A diluted mixture of TDAs is not irritating to the rabbit eye. | Air Products and Chemicals (1976)
Eye irritation | Rabbits were exposed to a mixture of 2,3- and 3,4-TDA in a “suitable vehicle” in eye. | Irritation score was 7/10. | A mixture of TDA isomers is irritating to the rabbit eye. | Carpenter et al. (1974)

CI = confidence interval; GI = gastrointestinal; i.p. = intraperitoneal; LC_50_ = median lethal concentration; LD_50_ = median lethal dose; s.c. = subcutaneous; TDA = toluenediamine.

### 2.3.3 Reproductive/Developmental Studies of TDA Mixtures

#### Becci et al. (1983)

Groups of 22 pregnant Sprague Dawley rats were administered o-TDA (a 40:60 mixture of 2,3- and 3,4-TDA) at doses of 0, 10, 30, 100, or 300 mg/kg-day via gavage in corn oil from Gestation Days (GDs) 6−15. Observations were conducted daily for general appearance, behavior, and mortality. Body weights of the dams were recorded on GDs 0, 6, 9, 12, 15, and 20. On GD 20, all dams were sacrificed, and uterine contents were removed and examined. One-half of the fetuses were examined for soft-tissue anomalies, and the remaining fetuses were examined for skeletal anomalies. No treatment-related effects on appearance or behavior were observed in treated dams, and all dams survived the duration of the study. There was a statistically significant decrease in weight gain (−20%) during gestation for treated dams receiving 300 mg/kg-day compared with controls. No significant differences in the number of live fetuses, implantation sites, or resorption sites were indicated. Fetal effects indicative of developmental delay included significant reductions in fetal body weight (−18%) in the 300-mg/kg-day group and significant increases in skeletal variations per litter (missing sternebrae at 300 mg/kg-day and incomplete ossification of vertebrae at 100 and 300 mg/kg-day), compared with controls. No exposure-related skeletal or soft-tissue malformations were observed. No maternal or developmental effects were seen at ≤30 mg/kg-day.

Additionally, groups of 15 pregnant Dutch belted rabbits were exposed to o-TDA at doses of 0, 3, 10, 30, or 100 mg/kg-day via gavage in corn oil from GDs 6−18. Observations were conducted daily for general appearance, behavior, and mortality. Body weights of the does were recorded on GDs 0, 6, 9, 12, 15, 18, and 29. On GD 29, all does were sacrificed, and uterine contents were removed and examined. All of the fetuses were examined for both soft-tissue and skeletal anomalies. Appearance and behavior of does were unaffected by treatment. All does survived the duration of the study. Body-weight gain during gestation was significantly decreased (−60%) in treated does receiving 100 mg/kg-day compared with controls. Other observations at this dose included a significant 2.5-fold increase in the incidence of resorptions, a 16% decrease in the mean number of live fetuses/doe (reported as statistically significant in the text, but not in the table showing the data), and a significant 22% decrease in fetal body weight. No exposure-related skeletal or soft-tissue malformations or variations were observed. No maternal or developmental effects were seen at ≤30 mg/kg-day.

#### BASF (2010)

In an OECD 421 reproductive/developmental (R/D) study available only as an industry-submitted summary, groups of male and female Wistar rats (10/sex/group) were administered o-TDA (45:50 mixture of 2,3- and 3,4-TDA) at doses of 0, 10, 50, or 250 mg/kg-day via gavage (vehicle not reported) from premating through mating (males, at least 28 days) or premating through Postnatal Day (PND) 4 (up to 60 days for females). The pups were sacrificed and examined on PND 4 (endpoints examined at sacrifice were not reported). The available summary reported only “the most relevant results”; no statistics were provided, and the summary did not include the magnitude/incidence for many of the findings.

Clinical signs of toxicity (reduced activity, eyelid drop, salivation, and/or piloerection) were observed in males and dams at ≥50 mg/kg-day. Decreased food consumption was observed during premating in males at 250 mg/kg-day and females at ≥50 mg/kg-day; decreased food consumption was also observed in dams during gestation at 250 mg/kg-day. Body-weight gain was decreased throughout the study in high-dose males, with a decreased terminal body weight compared with controls (magnitude not reported). Decreased body weight and body-weight gains were observed during premating and gestation in dams at 250 mg/kg-day, with a decreased terminal body weight compared with controls (magnitude not reported). In males, a decrease in the number of spermatids/g testis was reported at 250 mg/kg-day; however, the study summary did not indicate whether decreased fertility was observed. Reproductive effects observed in high-dose dams included a 39% decrease in the number of implantation sites compared with controls, a 27.4% post implantation loss (control value not reported), and a 42% decrease in the number of delivered pups/litter. In offspring, a decreased viability index of 91% was observed at 250 mg/kg-day (viability index in controls was not reported). No effects were noted in males or dams administered 10 mg/kg-day.

### 2.3.4 Mode-of-Action/Mechanistic Studies

Mechanistic data for 3,4-TDA are limited. Perkins and Green (1975) suggested that the duodenal ulcers observed by Selye (1973) may be a result of 3,4-TDA toxicity to Brunner’s glands in the proximal duodenum. Brunner’s glands function to secrete an alkaline mucoid material to protect the duodenum from the corrosive action of gastric juices. The volume of Brunner’s glands’ secretions was quantified in situ following single subcutaneous injections of 3,4-TDA in rats at 125 mg/kg (which caused minimal gastroduodenal damage), 350 mg/kg (which caused maximal duodenal damage and minimal mortality), and 500 mg/kg (which caused a low incidence of duodenal and a high incidence of gastric damage). The output of fluid from Brunner’s glands was significantly decreased in all exposed groups compared with control, with lower inhibition at 125 mg/kg (25%) than 350 and 500 mg/kg (61 and 57%, respectively).