# 1 INTRODUCTION

3,4-Toluenediamine (3,4-TDA), also known as 3,4-diaminotoluene (CASRN 496-72-0), belongs to the class of compounds known as anilines and is an ortho (o)-substituted compound. The principal commercial use for o-TDAs, including 3,4-TDA, is in the production of tolyltriazoles used in corrosion and nitrification inhibitors. 3,4-TDA is also used as an intermediate in the manufacture of urethane products, dyes, corrosion inhibitors, polyols, and benzimidazole thiol antioxidants and as a starting material for a pharmaceutical intermediate (Cartolano, 2005; HSDB, 2003). It is listed on U.S. EPA’s Toxic Substances Control Act’s public inventory (U.S. EPA, 2015), but it is not registered with Europe’s Registration, Evaluation, Authorisation and Restriction of Chemicals (REACH) program (ECHA, 2016).

TDA isomers, including 3,4-TDA, are produced by the catalytic hydrogenation of dinitrotoluenes under a variety of temperatures, pressures, and solvents. 3,4-TDA is then separated from meta (m)-substituted TDAs by vacuum distillation (Cartolano, 2005).

3,4-TDA is one of six TDA isomers that are components of crude or commercial-grade mixtures used as intermediates in the production of dyes and pigments for commercial products (WHO, 1987). The crude mixture contains all six isomeric forms, while the two commercial mixtures are composed primarily of two isomers each. One commercial mixture, m-TDA, contains the 2,4- and 2,6- isomers (80:20 or 65:35), and the other, o-TDA, contains the 2,3- and 3,4- isomers (40:60).

The empirical formula for 3,4-TDA is C_7_H_10_N_2_, and its structure is shown in Figure 1. Table 1 summarizes the physicochemical properties of 3,4-TDA. The compound is a light gray to purple solid at room temperature (Cartolano, 2005). The low vapor pressure and low estimated Henry’s law constant for 3,4-TDA indicate that it is unlikely to volatilize from either dry or moist surfaces. 3,4-TDA has an estimated atmospheric half-life of 0.6 hours for the reaction with hydroxyl radicals, but this is not expected to be an important fate process because the compound is not likely to partition to the atmosphere. The estimated water solubility and low soil adsorption coefficient for 3,4-TDA indicate that it has the potential to leach to groundwater or undergo runoff after a rain event. However, given its acid dissociation constant (pKa), 3,4-TDA may exist partially as a cation in the environment, and cations generally adsorb more strongly to soils containing organic carbon and clay than their neutral counterparts. Also, aromatic amines contain highly reactive amino groups that may cause strong bonding to soil organic matter.

Figure 1 3,4-Toluenediamine (CASRN 496-72-0) Structure

This is the beginning of the long description for Figure 1. Figure 1 is titled 3 4 Toluenediamine, C A S Registry Number 4 9 6 dash 7 2 dash 0, Structure. The chemical has the empirical formula of C 7 H 10 N 2. This is the end of the long description for Figure 1.

Table 1 Physicochemical Properties of 3,4-Toluenediamine (CASRN 496-72-0)

Property (unit) | Value^a^
Physical state | Solid^b^
Boiling point (°C) | 243
Melting point (°C) | 88.8
Density (g/cm^3^) | 1.13 (predicted)
Vapor pressure (mm Hg) | 6.29 × 10^−4^
pH (unitless) | NV
Acid dissociation constant (pKa) (unitless) | 5.00
Solubility in water (mol/L) | 2.39 (predicted)
Octanol-water partition coefficient (log K_ow_) | 0.66
Henry’s law constant (atm-m^3^/mol) | 5.59 × 10^−8^ (predicted)
Soil adsorption coefficient (K_oc_) (L/kg) | 31.3 (predicted)
Atmospheric OH rate constant (cm^3^/molecule-sec at 25°C) | 1.43 × 10^−10^ (predicted)
Atmospheric half-life (h) | 0.6 (predicted)^b^
Relative vapor density (air = 1) | NV
Molecular weight (g/mol) | 122
Flash point (°C) | 137 (predicted)

a Data were extracted from the U.S. EPA CompTox Chemicals Dashboard (3,4-Toluenediamine, CASRN 496-72-0. https://comptox.epa.gov/dashboard/DTXSID9024930. Accessed on April 20, 2021) . All values are experimental averages unless otherwise specified.

b U.S. EPA (2012).

NV = not available.

No toxicity values for 3,4-TDA are available from U.S. EPA or other agencies/organizations searched, as shown in Table 2.

Table 2 Summary of Available Toxicity Values for 3,4-Toluenediamine (CASRN 496-72-0)

Source^a^ | Value (applicability) | Notes | Reference^b^
Noncancer
IRIS | NV | NA | U.S. EPA (2020a)
HEAST | NV | NA | U.S. EPA (2011b)
DWSHA | NV | NA | U.S. EPA (2018)
ATSDR | NV | NA | ATSDR (2018)
IPCS | NV | NA | IPCS (2020)
CalEPA | NV | NA | CalEPA (2019)
OSHA | NV | NA | OSHA (2020a); OSHA (2020b)
NIOSH | NV | NA | NIOSH (2016)
ACGIH | NV | NA | ACGIH (2020)
Cancer
IRIS | NV | NA | U.S. EPA (2020a)
HEAST | NV | NA | U.S. EPA (2011b)
DWSHA | NV | NA | U.S. EPA (2018)
NTP | NV | NA | NTP (2016a)
IARC | NV | NA | IARC (2018)
CalEPA | NV | NA | CalEPA (2019)
ACGIH | NV | NA | ACGIH (2020)

a Sources: ACGIH = American Conference of Governmental Industrial Hygienists; ATSDR = Agency for Toxic Substances and Disease Registry; CalEPA = California Environmental Protection Agency; DWSHA = Drinking Water Standards and Health Advisories; HEAST = Health Effects Assessment Summary Tables; IARC = International Agency for Research on Cancer; IPCS = International Programme on Chemical Safety; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration.

b Reference date is the publication date for the database and not the date the source was accessed.

NA = not applicable; NV = not available.

Non-date-limited literature searches were conducted in November 2017 and updated in May 2020 and April 2021 for studies relevant to the derivation of provisional toxicity values for 3,4-toluenediamine (CASRN 496-72-0). Searches were conducted using U.S. EPA’s Health and Environmental Research Online (HERO) database of scientific literature. HERO searches the following databases: PubMed, TOXLINE^1^ (including TSCATS1), and Web of Science. The following resources were searched outside of HERO for health-related values: American Conference of Governmental Industrial Hygienists (ACGIH), Agency for Toxic Substances and Disease Registry (ATSDR), California Environmental Protection Agency (CalEPA), Defense Technical Information Center (DTIC), European Centre for Ecotoxicology and Toxicology of Chemicals (ECETOC), European Chemicals Agency (ECHA), U.S. EPA Chemical Data Access Tool (CDAT), U.S. EPA ChemView, U.S. EPA Integrated Risk Information System (IRIS), U.S. EPA Health Effects Assessment Summary Tables (HEAST), U.S. EPA Office of Water (OW), International Agency for Research on Cancer (IARC), U.S. EPA TSCATS2/TSCATS8e, U.S. EPA High Production Volume (HPV), Chemicals via IPCS INCHEM, Japan Existing Chemical Data Base (JECDB), Organisation for Economic Cooperation and Development (OECD) Screening Information Data Sets (SIDS), OECD International Uniform Chemical Information Database (IUCLID), OECD HPV, National Institute for Occupational Safety and Health (NIOSH), National Toxicology Program (NTP), Occupational Safety and Health Administration (OSHA), and World Health Organization (WHO).

1 Note that this version of TOXLINE (https://www.nlm.nih.gov/databases/download/toxlinesubset.html) is no longer updated; therefore, it was not included in the literature search updates from May 2020 and April 2021.