# APPENDIX D METHODOLOGY AND RESULTS FOR IN SILICO METABOLITE ANALYSIS OF TARGET AND ANALOGUES

An in silico analysis of metabolism was conducted for 3,4-toluenediamine (3,4-TDA) and its analogues using different software tools. The main objective of this analysis is to provide a qualitative comparison of metabolite predictions for TDA compounds in the absence of experimental data for the target. The focus is on the major metabolism pathways characterized in the literature, highlighting any notable differences between the target and analogues.

Chemical structures were extracted from the U.S. EPA CompTox Chemicals Dashboard for 3,4-TDA and the identified structural analogues [2,3-, 2,4-, 2,5-, and 2,6-TDA; U.S. EPA (2019)]. The metabolite predictions for the chemicals of interest were generated using commercially available software systems, including the Tissue Metabolism Simulator (TIMES) (Dimitrov et al., 2005; Mekenyan et al., 2004) and Meteor Nexus (Marchant et al., 2008). A structure data file (SDF) was imported into the TIMES program (Version 2.29.1; http://oasis-lmc.org/products/software/times.aspx), using the in vitro rat S9 metabolic simulator (Version 11.16) and the rat in vivo metabolic simulator (Version 07.12) to make predictions of likely metabolites. The predictions were exported as a .txt file for subsequent processing.

For the Meteor Nexus predictions, the SDF was split into separate molecular data (MOL) files for batch processing in Meteor Nexus. A python script (Python; Version 3.6.5; python.org) was used to split the SDF, and a second script was used to concatenate the individual substance prediction files that were created as separate excel workbooks. Default settings were used in Meteor Nexus (Version 3.1.0) developed by Lhasa Limited (https://www.lhasalimited.org/library/publishing.htm). The settings were for a maximum depth of tree to be 3, for the maximum number of metabolites to be capped at 1,000 and for the scoring method to be Site of Metabolism Scoring (with Molecular Mass Variance). The results are described as a score that uses experimental data for compounds that match the same biotransformation, have similar molecular weights and are structurally similar around the site of metabolism to the query compound (for more details, see https://www.lhasalimited.org/products/meteor-reasoning-methodologies.htm). The prediction files were then processed further within a Jupyter notebook (jupyter.org) imported with python libraries RDKit (Version 2018.03.2.0; RDKit.org), Pandas (Version 0.23.1; pandas.pydata.org), NumPy (Version 1.14.3; numpy.org), and Matplotlib (Version 2.2.2; matplotlib.org).

The software systems provided Simplified Molecular Input Line Entry System (SMILES) representations for the predicted metabolites. These were converted into RDKit mol objects and exported as a Pandas Tools worksheet that provided depictions of chemical structure. International Union of Pure and Applied Chemistry (IUPAC) International Chemical Identifier (InChI™) keys were created using RDKit because SMILES representations are not unique. The structures of the predicted metabolites from each of the tools evaluated are presented in Table D-1, which compares metabolites identified across the different software tools and experimental data from in vivo animal studies captured in Table A-3 of the “Metabolic Analogues” section in Appendix A. Additionally, pathway transformations corresponding to the metabolite predictions were extracted from Meteor Nexus to facilitate similarity comparisons between the target and candidate analogues. Other software tools (i.e., TIMES) did not provide the same level of information. The pathway transformations for target and candidate analogues were extracted from the Meteor Nexus summary report, then grouped by substance and pivoted to provide a representation of the TDA compounds as rows and the unique pathways as columns (see Table A-4 in Appendix A). A pairwise distance matrix was then computed using the Jaccard distance as a metric, which was then transformed to a similarity matrix (see Figure A-1 in Appendix A). A metabolic tree for the 2,4-TDA was constructed to highlight the relationships of predicted metabolites for this specific analogue that correspond to the pathway transformations shared among the TDA compounds (see Figure D-1).

Table D-1 Comparison of Metabolite Predictions for 3,4-Toluenediamine (CASRN 496-72-0) and Candidate Analogues across Software Tools and Observations from In Vivo Rodent Studies^a^

Structure | InChI Key | SMILES | Meteor Nexus^b^ | TIMES_In Vivo^c^ | TIMES_In Vitro^c^ | Observed In Vivo^d^
3,4-Toluenediamine (CASRN 496-72-0)
structure diagram | CDOUPQQJGFCACL-UHFFFAOYSA-N | CC(=O)Nc1cc(C)ccc1N | 1 | 1 | 1 | NDr
structure diagram | JBJRVPVZADJOOX-UHFFFAOYSA-N | CC(=O)Nc1ccc(C)cc1N | 1 | 1 | 1 | NDr
structure diagram | LXBXLRPRAMALBT-UHFFFAOYSA-N | Cc1cc(N)c(N)cc1O | 1 | 1 | 1 | NDr
structure diagram | AMUSQFJRRCHIDJ-UHFFFAOYSA-N | Cc1ccc(N)c(NO)c1 | 1 | 0 | 1 | NDr
structure diagram | HEMGYNNCNNODNX-UHFFFAOYSA-N | Nc1ccc(C(=O)O)cc1N | 1 | 0 | 1 | NDr
structure diagram | HMVJXTUUQJUYJI-UHFFFAOYSA-N | Nc1ccc(CO)cc1N | 1 | 0 | 1 | NDr
structure diagram | LQKOQGZAAWXAJO-UHFFFAOYSA-N | Cc1ccc(NO)c(N)c1 | 1 | 0 | 1 | NDr
structure diagram | FQQXRJHNPCQKQB-UHFFFAOYSA-N | Cc1cc(N)c(N)c(O)c1 | 0 | 1 | 1 | NDr
structure diagram | AELQHYALRZNYNG-UHFFFAOYSA-N | CC(=O)Nc1ccc(C)cc1NO | 1 | 0 | 0 | NDr
structure diagram | CDBLIIZYTJQRIR-UHFFFAOYSA-N | Cc1ccc(NOS(=O)(=O)O)c(N)c1 | 1 | 0 | 0 | NDr
structure diagram | CFFKPFQMLZQSMC-UHFFFAOYSA-N | CC(=O)Nc1ccc(CO)cc1N | 1 | 0 | 0 | NDr
structure diagram | DMIWVGYENDrUAGJ-UHFFFAOYSA-N | Cc1ccc(N)c(NOS(=O)(=O)O)c1 | 1 | 0 | 0 | NDr
structure diagram | OYMWICMADIVGJD-UHFFFAOYSA-N | Nc1ccc(CO)cc1NO | 1 | 0 | 0 | NDr
structure diagram | OYXHIBSVHUIIHN-UHFFFAOYSA-N | CC(=O)Nc1cc(C)ccc1NO | 1 | 0 | 0 | NDr
structure diagram | YPMPQTKAGFCMHX-UHFFFAOYSA-N | Nc1cc(CO)ccc1NO | 1 | 0 | 0 | NDr
structure diagram | ZSHDMSDVKOVLAA-UHFFFAOYSA-N | CC(=O)Nc1cc(CO)ccc1N | 1 | 0 | 0 | NDr
structure diagram | CFNITIXCKKIDKK-UHFFFAOYSA-N | CC(=O)Nc1cc(O)c(C)cc1N | 0 | 1 | 0 | NDr
structure diagram | IHUHNLWFEHPZOR-UHFFFAOYSA-N | CC(=O)Nc1cc(C)c(O)cc1N | 0 | 1 | 0 | NDr
structure diagram | RHCSARHFCNPXNQ-UHFFFAOYSA-N | CC(=O)Nc1cc(C)cc(O)c1N | 0 | 1 | 0 | NDr
structure diagram | VRFLCZIWWHOCPA-UHFFFAOYSA-N | CC(=O)Nc1c(N)cc(C)cc1O | 0 | 1 | 0 | NDr
structure diagram | AIYGLIJSQZZWPP-UHFFFAOYSA-N | Cc1ccc(N=O)c(N)c1 | 0 | 0 | 1 | NDr
structure diagram | CFDDUZIKVUIONZ-UHFFFAOYSA-N | Cc1ccc(N(O)SCC(NC(=O)CCC(N)C(=O)O)C(=O)NCC(=O)O)c(N)c1 | 0 | 0 | 1 | NDr
structure diagram | FGMJURDRCOTDCZ-UHFFFAOYSA-N | Cc1ccc(N)c(N(O)SCC(NC(=O)CCC(N)C(=O)O)C(=O)NCC(=O)O)c1 | 0 | 0 | 1 | NDr
structure diagram | GMFRNXFZQNBPLZ-UHFFFAOYSA-N | CC1=CC(=N)C(N)=CC1=O | 0 | 0 | 1 | NDr
structure diagram | GMPOLBFESRQGCU-UHFFFAOYSA-N | Cc1ccc(N)c(N=O)c1 | 0 | 0 | 1 | NDr
structure diagram | NAGMCFVTHPBBFR-UHFFFAOYSA-N | Cc1c(O)cc(N)c(N)c1SCC(NC(=O)CCC(N)C(=O)O)C(=O)NCC(=O)O | 0 | 0 | 1 | NDr
structure diagram | NSILMBMDJGSYNS-UHFFFAOYSA-N | Nc1ccc(C=O)cc1N | 0 | 0 | 1 | NDr
structure diagram | QAFMNLZTMYPOOY-UHFFFAOYSA-N | CC1(SCC(NC(=O)CCC(N)C(=O)O)C(=O)NCC(=O)O)CC(=N)C(N)=CC1=O | 0 | 0 | 1 | NDr
structure diagram | UVIYTNUYRRBTME-UHFFFAOYSA-N | Nc1cc(C=O)cc(O)c1N | 0 | 0 | 1 | NDr
structure diagram | YXTRRMZKHFFNPW-UHFFFAOYSA-N | Nc1cc(CO)cc(O)c1N | 0 | 0 | 1 | NDr
2,3-Toluenediamine (CASRN 2687-25-4)
structure diagram | CDQDPNFLCSCJCH-UHFFFAOYSA-N | CC(=O)Nc1c(C)cccc1N | 1 | 1 | 1 | NDr
structure diagram | LQAAALNVGAFVJD-UHFFFAOYSA-N | CC(=O)Nc1cccc(C)c1N | 1 | 1 | 1 | NDr
structure diagram | FQKUNAYBPMGVRP-UHFFFAOYSA-N | Cc1cccc(N)c1NO | 1 | 0 | 1 | NDr
structure diagram | FYUDUZRLZITSTF-UHFFFAOYSA-N | Nc1cccc(CO)c1N | 1 | 0 | 1 | NDr
structure diagram | KKTUQAYCCLMNOA-UHFFFAOYSA-N | Nc1cccc(C(=O)O)c1N | 1 | 0 | 1 | NDr
structure diagram | VYFFPFYOFVMNGG-UHFFFAOYSA-N | Cc1cccc(NO)c1N | 1 | 0 | 1 | NDr
structure diagram | GVEXOXFTENPDOH-UHFFFAOYSA-N | Cc1c(O)ccc(N)c1N | 0 | 1 | 1 | NDr
structure diagram | SRFOBSMZHWJDJN-UHFFFAOYSA-N | Cc1cc(O)cc(N)c1N | 0 | 1 | 1 | NDr
structure diagram | DCYIPFHDKQUXBG-UHFFFAOYSA-N | Cc1cccc(N)c1NOS(=O)(=O)O | 1 | 0 | 0 | NDr
structure diagram | DEYTUXOGDHQHRY-UHFFFAOYSA-N | CC(=O)Nc1cccc(CO)c1N | 1 | 0 | 0 | NDr
structure diagram | GMTRKMQJURSNIX-UHFFFAOYSA-N | CC(=O)Nc1cccc(C)c1NO | 1 | 0 | 0 | NDr
structure diagram | HRGIXVSYYVWOGJ-UHFFFAOYSA-N | Nc1c(CO)cccc1NO | 1 | 0 | 0 | NDr
structure diagram | LFOLOGIZBFISKF-UHFFFAOYSA-N | Nc1cccc(CO)c1NO | 1 | 0 | 0 | NDr
structure diagram | YJDFBYAXTGPZSK-UHFFFAOYSA-N | Cc1cccc(NOS(=O)(=O)O)c1N | 1 | 0 | 0 | NDr
structure diagram | YRXPMBZXLPQXIS-UHFFFAOYSA-N | CC(=O)Nc1c(N)cccc1CO | 1 | 0 | 0 | NDr
structure diagram | ZPZCAEZFJLLBMW-UHFFFAOYSA-N | CC(=O)Nc1c(C)cccc1NO | 1 | 0 | 0 | NDr
structure diagram | FUVMDOMRPMZMOA-UHFFFAOYSA-N | CC(=O)Nc1ccc(O)c(C)c1N | 0 | 1 | 0 | NDr
structure diagram | HBCUEGKUEMKCKO-UHFFFAOYSA-N | CC(=O)Nc1c(N)ccc(O)c1C | 0 | 1 | 0 | NDr
structure diagram | PNMPOSDTYOCRAS-UHFFFAOYSA-N | CC(=O)Nc1c(C)cc(O)cc1N | 0 | 1 | 0 | NDr
structure diagram | ZEBMHLAASWFAGS-UHFFFAOYSA-N | CC(=O)Nc1cc(O)cc(C)c1N | 0 | 1 | 0 | NDr
structure diagram | ARCDFSYMTMSQRI-UHFFFAOYSA-N | CC1=CC(=O)C=C(N)C1=O | 0 | 0 | 1 | NDr
structure diagram | CCIQDILKNGQPCA-UHFFFAOYSA-N | N=C1C(N)=CC(=O)C=C1CO | 0 | 0 | 1 | NDr
structure diagram | FTKYIFRLYMBQDC-UHFFFAOYSA-N | CC1=C(N)C(=N)CC(SCC(NC(=O)CCC(N)C(=O)O)C(=O)NCC(=O)O)C1=O | 0 | 0 | 1 | NDr
structure diagram | NAJRDVTXZXCQAM-UHFFFAOYSA-N | Cc1cccc(N=O)c1N | 0 | 0 | 1 | NDr
structure diagram | NRERCLGIEBGCTA-UHFFFAOYSA-N | Cc1cccc(N)c1N(O)SCC(NC(=O)CCC(N)C(=O)O)C(=O)NCC(=O)O | 0 | 0 | 1 | NDr
structure diagram | PMJTXIMMLKKLKL-UHFFFAOYSA-N | Cc1cccc(N)c1N=O | 0 | 0 | 1 | NDr
structure diagram | PYGSXASUOAHHOW-UHFFFAOYSA-N | Cc1cccc(N(O)SCC(NC(=O)CCC(N)C(=O)O)C(=O)NCC(=O)O)c1N | 0 | 0 | 1 | NDr
structure diagram | RJICMTPCHYXVJA-UHFFFAOYSA-N | CC1=C(N)C(=N)C=CC1=O | 0 | 0 | 1 | NDr
structure diagram | UOGKMJUEKOCDAX-UHFFFAOYSA-N | Nc1cccc(C=O)c1N | 0 | 0 | 1 | NDr
structure diagram | VVDQVHPTNDVFMR-UHFFFAOYSA-N | CC1=CC(=O)C=C(N)C1=N | 0 | 0 | 1 | NDr
structure diagram | WWYXBGROOLIEEU-UHFFFAOYSA-N | Cc1c(O)cc(SCC(NC(=O)CCC(N)C(=O)O)C(=O)NCC(=O)O)c(N)c1N | 0 | 0 | 1 | NDr
2,4-Toluenediamine (CASRN 95-80-7)
structure diagram | DPKOCFTZJRJTQL-UHFFFAOYSA-N | Cc1cc(O)c(N)cc1N | 1 | 1 | 1 | 1
structure diagram | RBQWGHBZCHFUQU-UHFFFAOYSA-N | CC(=O)Nc1ccc(C)c(N)c1 | 1 | 1 | 1 | 1
structure diagram | UAZGSMMESOKKQZ-UHFFFAOYSA-N | CC(=O)Nc1cc(N)ccc1C | 1 | 1 | 1 | NDr
structure diagram | BATBGGSVKZESGJ-UHFFFAOYSA-N | CC(=O)Nc1cc(N)c(C)cc1O | 1 | 1 | 0 | 1
structure diagram | FADNCTVVKDWKIX-UHFFFAOYSA-N | Nc1ccc(CO)c(N)c1 | 1 | 0 | 1 | NDr
structure diagram | JCSKFCJYMXDFAD-UHFFFAOYSA-N | Cc1ccc(NO)cc1N | 1 | 0 | 1 | NDr
structure diagram | KARRBUHHWCMGHB-UHFFFAOYSA-N | Cc1ccc(N)cc1NO | 1 | 0 | 1 | NDr
structure diagram | LDQMZKBIBRAZEA-UHFFFAOYSA-N | Nc1ccc(C(=O)O)c(N)c1 | 1 | 0 | 1 | NDr
structure diagram | LZEMQCKKBQRKFM-UHFFFAOYSA-N | CC(=O)Nc1cc(N)c(O)cc1C | 1 | 1 | 0 | NDr
structure diagram | CEKKEYTVRSICNQ-UHFFFAOYSA-N | Cc1cc(O)c(N)c(SCC(NC(=O)CCC(N)C(=O)O)C(=O)NCC(=O)O)c1N | 1 | 0 | 0 | NDr
structure diagram | DYLOOKKMCKMECT-UHFFFAOYSA-N | Cc1ccc(N=O)cc1N | 1 | 0 | 0 | NDr
structure diagram | IODXTXYTNSSKSC-UHFFFAOYSA-N | Cc1ccc(N)cc1N(O)SCC(NC(=O)CCC(N)C(=O)O)C(=O)NCC(=O)O | 1 | 0 | 0 | NDr
structure diagram | LLROHMIZNDXUDK-UHFFFAOYSA-N | Cc1ccc(N)cc1N=O | 1 | 0 | 0 | NDr
structure diagram | RGMVILWFQAJIRO-UHFFFAOYSA-N | CC1=CC(=O)C(N)(SCC(NC(=O)CCC(N)C(=O)O)C(=O)NCC(=O)O)CC1=N | 1 | 0 | 0 | NDr
structure diagram | VMFJRVFZHAPENO-UHFFFAOYSA-N | Nc1ccc(C=O)c(N)c1 | 1 | 0 | 0 | NDr
structure diagram | YIJGNYPGRJIBNG-UHFFFAOYSA-N | CC1=CC(=O)C(N)=CC1=N | 1 | 0 | 0 | NDr
structure diagram | YLDTVWMQWTYLOW-UHFFFAOYSA-N | Cc1ccc(N(O)SCC(NC(=O)CCC(N)C(=O)O)C(=O)NCC(=O)O)cc1N | 1 | 0 | 0 | NDr
structure diagram | DGBUOAIABOATGK-UHFFFAOYSA-N | CC(=O)Nc1cc(N)ccc1CO | 1 | 0 | 0 | NDr
structure diagram | HJLRPSJGXCSTOA-UHFFFAOYSA-N | CC(=O)Nc1ccc(C)c(NO)c1 | 1 | 0 | 0 | NDr
structure diagram | NNYGTEAPVBYVOR-UHFFFAOYSA-N | Cc1cc(OS(=O)(=O)O)c(N)cc1N | 0 | 0 | 1 | NDr
structure diagram | NTVDFUPWAZHKRU-UHFFFAOYSA-N | Cc1ccc(NOS(=O)(=O)O)cc1N | 0 | 0 | 1 | NDr
structure diagram | OHWHMZFQZAEYNR-UHFFFAOYSA-N | Nc1cc(NO)ccc1CO | 0 | 0 | 1 | NDr
structure diagram | PQHCWNHKWOJEJH-UHFFFAOYSA-N | CC(=O)Nc1cc(NO)ccc1C | 0 | 0 | 1 | NDr
structure diagram | ULBRTOCNNKAALW-UHFFFAOYSA-N | CC(=O)Nc1ccc(CO)c(N)c1 | 0 | 0 | 1 | NDr
structure diagram | WQJKPERQJHMQFH-UHFFFAOYSA-N | Nc1ccc(CO)c(NO)c1 | 0 | 0 | 1 | NDr
structure diagram | XKZAGZAKKCRYJI-UHFFFAOYSA-N | Nc1cc(N)c(CO)cc1O | 0 | 0 | 1 | NDr
structure diagram | YEDHXAKCFRBZAC-UHFFFAOYSA-N | Cc1ccc(N)cc1NOS(=O)(=O)O | 0 | 0 | 1 | NDr
structure diagram | IFQWBWVICSDDSO-UHFFFAOYSA-N | C1=C(C(=CC=C1NC(C)=O)C(=O)O)N | 0 | 0 | 0 | 1
structure diagram | RMHSOFVBSGKWJZ-UHFFFAOYSA-N | C1(=C(C=CC(=C1O)N)C)N | 0 | 0 | 0 | 1
structure diagram | UZDRYZZYGHVZBF-UHFFFAOYSA-N | C1=CC(=C(C(=C1C)N)O)NC(C)=O | 0 | 0 | 0 | 1
structure diagram | UZGYKGBZSGOYCM-UHFFFAOYSA-N | C1=CC(=C(C=C1NC(C)=O)NC(C)=O)C(=O)O | 0 | 0 | 0 | 1
structure diagram | XAHUNQAOCGDSBW-UHFFFAOYSA-N | C1(=CC=C(C=C1NC(C)=O)NC(C)=O)C | 0 | 0 | 0 | 1
structure diagram | YKMOHRBCUQRNQM-UHFFFAOYSA-N | C1=C(C=C(C(=C1O)C)N)N | 0 | 0 | 0 | 1
structure diagram | IFQWBWVICSDDSO-UHFFFAOYSA-N | C1=C(C(=CC=C1NC(C)=O)C(=O)O)N | 0 | 0 | 0 | 1
2,5-Toluenediamine (CASRN 95-70-5)
structure diagram | GWFPMSIIVJMYRZ-UHFFFAOYSA-N | CC(=O)Nc1ccc(N)cc1C | 1 | 1 | 1 | NDr
structure diagram | LJHMYKUSHZQTMV-UHFFFAOYSA-N | Cc1cc(N)ccc1NO | 1 | 0 | 1 | NDr
structure diagram | NKNCGBHPGCHYCQ-UHFFFAOYSA-N | Nc1ccc(N)c(CO)c1 | 1 | 0 | 1 | NDr
structure diagram | QNLWDEIYRQGAEE-UHFFFAOYSA-N | Cc1cc(NO)ccc1N | 1 | 0 | 1 | NDr
structure diagram | QXWUFIZOBXUMSM-UHFFFAOYSA-N | CC(=O)Nc1ccc(N)c(C)c1 | 1 | 1 | 1 | NDr
structure diagram | UONVFNLDGRWLKF-UHFFFAOYSA-N | Nc1ccc(N)c(C(=O)O)c1 | 1 | 0 | 1 | NDr
structure diagram | AHAAQFCJXQOJQM-UHFFFAOYSA-N | Cc1cc(N)ccc1NOS(=O)(=O)O | 1 | 0 | 0 | NDr
structure diagram | BAYXOGMUGKSOIY-UHFFFAOYSA-N | Cc1cc(N)c(O)cc1N | 1 | 0 | 0 | NDr
structure diagram | GDRJGNLVIHNOTC-UHFFFAOYSA-N | CC(=O)Nc1cc(O)c(N)cc1C | 1 | 0 | 0 | NDr
structure diagram | JCEYYZACUKLBJT-UHFFFAOYSA-N | CC(=O)Nc1cc(C)c(N)cc1O | 1 | 0 | 0 | NDr
structure diagram | LPVMVIHWFLVFLL-UHFFFAOYSA-N | Nc1cc(CO)c(N)cc1O | 1 | 0 | 0 | NDr
structure diagram | OJKNEPYQGJFQCX-UHFFFAOYSA-N | CC(=O)Nc1ccc(NO)cc1C | 1 | 0 | 0 | NDr
structure diagram | PJLKOWKKMQTFPM-UHFFFAOYSA-N | Cc1cc(NOS(=O)(=O)O)ccc1N | 1 | 0 | 0 | NDr
structure diagram | PMHSKYOPGGHUCD-UHFFFAOYSA-N | Nc1ccc(NO)cc1CO | 1 | 0 | 0 | NDr
structure diagram | QWRHGJVFZGEQMN-UHFFFAOYSA-N | CC(=O)Nc1ccc(NO)c(C)c1 | 1 | 0 | 0 | NDr
structure diagram | QWUDZFZVWQFZNJ-UHFFFAOYSA-N | CC(=O)Nc1ccc(N)c(CO)c1 | 1 | 0 | 0 | NDr
structure diagram | WJQKIKWBEAJBTM-UHFFFAOYSA-N | CC(=O)Nc1ccc(N)cc1CO | 1 | 0 | 0 | NDr
structure diagram | YFLDRIRBIYOFLP-UHFFFAOYSA-N | Nc1ccc(NO)c(CO)c1 | 1 | 0 | 0 | NDr
structure diagram | CJGYEDFJVQTRDO-UHFFFAOYSA-N | Cc1c(N)ccc(N)c1SCC(NC(=O)CCC(N)C(=O)O)C(=O)NCC(=O)O | 0 | 0 | 1 | NDr
structure diagram | GAANDMBIVOKAES-UHFFFAOYSA-N | Cc1cc(N)c(SCC(NC(=O)CCC(N)C(=O)O)C(=O)NCC(=O)O)cc1N | 0 | 0 | 1 | NDr
structure diagram | GFXJDKBBELRHKA-UHFFFAOYSA-N | Cc1cc(N)cc(SCC(NC(=O)CCC(N)C(=O)O)C(=O)NCC(=O)O)c1N | 0 | 0 | 1 | NDr
structure diagram | GVAJQXAWDPTTRS-UHFFFAOYSA-N | Cc1cc(N)ccc1N(O)SCC(NC(=O)CCC(N)C(=O)O)C(=O)NCC(=O)O | 0 | 0 | 1 | NDr
structure diagram | KIWGKZZMXPLHDG-UHFFFAOYSA-N | Nc1ccc(N)c(C=O)c1 | 0 | 0 | 1 | NDr
structure diagram | LDEKAEXXYZEVAI-UHFFFAOYSA-N | Cc1cc(N(O)SCC(NC(=O)CCC(N)C(=O)O)C(=O)NCC(=O)O)ccc1N | 0 | 0 | 1 | NDr
structure diagram | LFHSUMCUWFSVFL-UHFFFAOYSA-N | CC1=CC(=N)C=CC1=N | 0 | 0 | 1 | NDr
structure diagram | UFBHQACBYVXASE-UHFFFAOYSA-N | Cc1cc(N=O)ccc1N | 0 | 0 | 1 | NDr
structure diagram | XIRVYFRBHGMGMO-UHFFFAOYSA-N | Cc1cc(N)ccc1N=O | 0 | 0 | 1 | NDr
structure diagram | ZYCWUKASEILJBB-UHFFFAOYSA-N | C1(=CC(=CC=C1NC(C)=O)NC(C)=O)C | 0 | 0 | 0 | 1
2,6-Toluenediamine (CASRN 823-40-5)
structure diagram | CIEFZSDJGQKZNS-UHFFFAOYSA-N | Nc1cccc(N)c1C(=O)O | 1 | 0 | 1 | NDr
structure diagram | NVKFKABKBGAWBK-UHFFFAOYSA-N | Cc1c(N)cccc1NO | 1 | 0 | 1 | NDr
structure diagram | TZEOVCYRUCGICH-UHFFFAOYSA-N | CC(=O)Nc1cccc(N)c1C | 1 | 1 | 1 | 1
structure diagram | ZJRAQHULMYRRQG-UHFFFAOYSA-N | Nc1cccc(N)c1CO | 1 | 0 | 1 | NDr
structure diagram | SHWMCLVULOXIMZ-UHFFFAOYSA-N | Cc1c(N)ccc(O)c1N | 0 | 1 | 1 | 1
structure diagram | BIMQURICJYBVBU-UHFFFAOYSA-N | Cc1c(N)cccc1NOS(=O)(=O)O | 1 | 0 | 0 | NDr
structure diagram | DPFBFFAJBRRLGH-UHFFFAOYSA-N | Nc1cccc(NO)c1CO | 1 | 0 | 0 | NDr
structure diagram | FHWODLDYCOFLFK-UHFFFAOYSA-N | CC(=O)Nc1cccc(N)c1CO | 1 | 0 | 0 | NDr
structure diagram | LNZDEXXJPTWLTL-UHFFFAOYSA-N | CC(=O)Nc1cccc(NO)c1C | 1 | 0 | 0 | NDr
structure diagram | POQKQLONFCRNFP-UHFFFAOYSA-N | CC(=O)Nc1c(O)ccc(N)c1C | 0 | 1 | 0 | NDr
structure diagram | FCSVJIUNOCBBTJ-UHFFFAOYSA-N | CC1=C(N)C(=O)C(SCC(NC(=O)CCC(N)C(=O)O)C(=O)NCC(=O)O)CC1=N | 0 | 0 | 1 | NDr
structure diagram | KWPKZWQEAFVXHD-UHFFFAOYSA-N | Cc1c(N)cccc1N(O)SCC(NC(=O)CCC(N)C(=O)O)C(=O)NCC(=O)O | 0 | 0 | 1 | NDr
structure diagram | PXORAQVFLKLDLZ-UHFFFAOYSA-N | CC1=C(N)C(=O)C=CC1=N | 0 | 0 | 1 | NDr
structure diagram | QWENKMCDOWMUAG-UHFFFAOYSA-N | Nc1cccc(N)c1C=O | 0 | 0 | 1 | NDr
structure diagram | VOOYTMAMLLHBSZ-UHFFFAOYSA-N | Cc1c(N)cccc1N=O | 0 | 0 | 1 | NDr
structure diagram | YPGMZCDVNOMVOG-UHFFFAOYSA-N | Cc1c(N)c(O)cc(SCC(NC(=O)CCC(N)C(=O)O)C(=O)NCC(=O)O)c1N | 0 | 0 | 1 | NDr
structure diagram | KSPKSSDXPVUERG-UHFFFAOYSA-N | CC(=O)Nc1ccc(O)c(N)c1C | 0 | 1 | 0 | 1
structure diagram | NAXDRCLBFGZQSR-UHFFFAOYSA-N | C1(=C(C=CC=C1NC(C)=O)NC(C)=O)C | 0 | 0 | 0 | 1

a 1/0 denotes whether a metabolite was identified/not identified by a software tool or experimental animal data captured in Table A-3.

b Meteor Nexus (Dimitrov et al., 2005; Mekenyan et al., 2004).

c In Vivo/In Vitro Rat Tissue Metabolism Simulator (Dimitrov et al., 2005; Mekenyan et al., 2004).

d Metabolites reported from in vivo animal studies for the TDA isomers. Experimental data for 2,3- and 3,4-TDA were not available. Refer to Table A-3 for additional details.

InChI = IUPAC International Chemical Identifier; IUPAC = International Union of Pure and Applied Chemistry; NDr = not determined; SMILES = Simplified Molecular Input Line Entry System; TDA = toluenediamine; TIMES = Tissue Metabolism Simulator.

Figure D-1 Metabolic Tree for the 2,4-Toluenediamine (CASRN 95-80-7) Analogue

Diagram displays the relationship of the metabolites identified from Meteor Nexus (Dimitrov et al., 2005; Mekenyan et al., 2004) to the parent compound and notes the corresponding pathway transformations (a–g).