# AUTHORS, CONTRIBUTORS, AND REVIEWERS

## CHEMICAL MANAGER

- Lucina E. Lizarraga, PhD
  Center for Public Health and Environmental Assessment, Cincinnati, OH

## CONTRIBUTOR

- Grace Patlewicz, PhD
  Center for Computational Toxicology and Exposure, Research Triangle Park, NC

## SCIENTIFIC TECHNICAL LEAD

- Jeffry L. Dean II, PhD
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- Q. Jay Zhao, PhD, MPH, DABT
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- J. Phillip Kaiser, PhD, DABT
  Center for Public Health and Environmental Assessment, Cincinnati, OH

## DRAFT DOCUMENT PREPARED BY

- SRC, Inc.
  7502 Round Pond Road
  North Syracuse, NY 13212

## PRIMARY INTERNAL REVIEWERS

- Q. Jay Zhao, PhD, MPH, DABT
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- Ingrid Druwe, PhD
  Center for Public Health and Environmental Assessment, Cincinnati, OH

## PRIMARY EXTERNAL REVIEW

- Eastern Research Group, Inc.
  110 Hartwell Avenue
  Lexington, MA 02421-3136

## PPRTV PROGRAM MANAGEMENT

- Teresa L. Shannon
  Center for Public Health and Environmental Assessment, Cincinnati, OH
- J. Phillip Kaiser, PhD, DABT
  Center for Public Health and Environmental Assessment, Cincinnati, OH

Questions regarding the content of this PPRTV assessment should be directed to the U.S. EPA Office of Research and Development (ORD) Center for Public Health and Environmental Assessment (CPHEA) website at https://ecomments.epa.gov/pprtv.