# 2 REVIEW OF POTENTIALLY RELEVANT DATA (NONCANCER AND CANCER)

As shown in Tables 3A and 3B, there are no potentially relevant subchronic or chronic studies or developmental or reproductive toxicity studies of 2,3-TDA in humans or animals for noncancer and cancer endpoints following oral or inhalation exposures. WHO (1987) described a small number of occupational health surveys of male workers exposed to diaminotoluene and dinitrotoluene mixtures; however, these studies are not useful for determining the effects of 2,3-TDA because they did not discuss or otherwise verify the presence of this isomer in the mixtures. The phrase “statistical significance” and term “significant,” used throughout the document, indicate a p-value of < 0.05 unless otherwise specified.

Table 3A Summary of Potentially Relevant Noncancer Data for 2,3-Toluenediamine (CASRN 2687-25-4)

Category | Number of Male/Female, Strain, Species, Study Type, Reported Doses, Study Duration | Dosimetry | Critical Effects | Reference | Notes
Human
1. Oral (mg/kg-d)
ND
2. Inhalation (mg/m^3^)
ND
Animal
1. Oral (mg/kg-d)
ND
2. Inhalation (mg/m^3^)
ND

ND = no data.

Table 3B Summary of Potentially Relevant Cancer Data for 2,3-Toluenediamine (CASRN 2687-25-4)

Category | Number of Male/Female, Strain, Species, Study Type, Reported Doses, Study Duration | Dosimetry | Critical Effects | Reference | Notes
Human
1. Oral (mg/kg-d)
ND
2. Inhalation (mg/m^3^)
ND
Animal
1. Oral (mg/kg-d)
ND
2. Inhalation (mg/m^3^)
ND

ND = no data.

## 2.1 HUMAN STUDIES

### 2.1.1 Oral Exposures

No human studies following oral exposure to 2,3-TDA have been identified.

### 2.1.2 Inhalation Exposures

No human studies following inhalation exposure to 2,3-TDA have been identified.

## 2.2 ANIMAL STUDIES

### 2.2.1 Oral Exposures

No animal studies following oral exposure to 2,3-TDA have been identified.

### 2.2.2 Inhalation Exposures

No animal studies following inhalation exposure to 2,3-TDA have been identified.

## 2.3 OTHER DATA (SHORT-TERM TESTS, OTHER EXAMINATIONS)

Toxicity data available for the 2,3-TDA isomer are limited to two genotoxicity studies. Toxicity studies evaluating TDA mixtures containing the 2,3-TDA isomer include a reproductive/toxicity study, two developmental toxicity studies, several acute lethality studies, eye and skin irritation assays, and a genotoxicity study.

### 2.3.1 Genotoxicity

Limited data are available on the genotoxicity of 2,3-TDA. Cheung et al. (1996) reported that 2,3-TDA (0, 5, 10, 15, and 20 µg/plate) was weakly mutagenic in Salmonella typhimurium strain TA98 with metabolic activation. The use of liver microsomes from rats treated with either Aroclor 1254 (a potent inducer of CYP1A enzymes) or the parent compound (i.e., 2,3-TDA) did not alter the mutagenic response. Administration of 0.2 or 0.5 mg/kg of 2,3-TDA by intraperitoneal (i.p.) injection did not cause an increase in chromosomal aberrations (CAs) or mitotic frequency in bone marrow or ascites tumor cells in male CFW mice (Adam, 1985). Similarly, the CA frequency was not increased in ascites tumor cells implanted in mice that were exposed subcutaneously to o-TDA (a mixture of 2,3- and 3,4-toluenediamine [3,4-TDA]) 4 days after implantation [Bogajewski and Bogajewska (1982), available only as an abstract].

### 2.3.2 Acute Toxicity Studies of TDA Mixtures

Available acute toxicity studies of TDA mixtures including 2,3-TDA are summarized in Table 4. Oral median lethal dose (LD_50_) values in rats for mixtures including 2,3-TDA range from 660 to 1,760 mg/kg (Dow Chemical, 1993, 1983; WIL Research, 1978; Air Products and Chemicals, 1976; Carpenter et al., 1974). An inhalation median lethal concentration (LC_50_) value >670 ppm was reported in rats exposed to a mixture of 2,3- and 3,4-TDA; the duration of exposure was not reported (Air Products and Chemicals, 1976). Exposure to concentrated vapors of a mixture of 2,3- and 3,4-TDA was lethal after >8 hours of exposure (Carpenter et al., 1974). Dermal LD_50_ values in rabbits exposed to mixtures of 2,3- and 3,4-TDA ranged from 1,120 to >5,750 mg/kg (Air Products and Chemicals, 1976; Carpenter et al., 1974). TDA mixtures including 2,3-TDA are slightly to moderately irritating to rabbit skin, and the undiluted liquid is irritating to the rabbit eye (Dow Chemical, 1993, 1983; Air Products and Chemicals, 1976; Carpenter et al., 1974). Skin sensitization was “insignificant” in guinea pigs exposed to a mixture of 2,3- and 3,4-TDA (Air Products and Chemicals, 1976).

Table 4 Acute Toxicity Studies with Exposure to TDA Mixtures

Test | Materials and Methods | Results | Conclusions | References
Acute oral lethality | Rats were exposed to a mixture of 2,3- and 3,4-TDA in 4% aqueous solution by gavage at 6 doses. Study was reported in tabular form with no further details. | LD_50_ = 660 mg/kg. No further details were provided. | Rat oral LD_50_ = 660 mg/kg. | Air Products and Chemicals (1976)
Acute oral lethality | Female rats were exposed orally to mixtures of 2,3- and 2,5-TDA (90–95%) and 2,4- and 2,6-TDA (10–15%). No further details provided. | LD_50_ ≈ 1,000 mg/kg. No further details were provided. | Rat oral LD_50_ ≈ 1,000 mg/kg. | Dow Chemical (1983); Dow Chemical (1993)
Acute oral lethality | Rats were exposed to a mixture of 2,3- and 3,4-TDA. No further details were provided. | LD_50_ (95% CI) = 810 (590–1,120) mg/kg. No further details were provided. | Rat oral LD_50_ = 810 mg/kg. | Carpenter et al. (1974)
Acute oral lethality | Sprague Dawley rats (5/sex/group) were exposed to two mixtures containing 2,3-, 2,4-, and 3,4-TDA and 4,4-methylenedianiline at doses of 0, 310, 630, or 1,250 mg/kg via gavage in corn oil. One formulation contained 11.95% (wt) 2,3-TDA; the other was a similar formulation, but exact percentages were not “precisely known.” The animals were observed hourly for the first 6 h for signs of toxicity, and subsequently for 14 d for mortality. Gross necropsies were performed. | Most deaths occurred between 1 and 3 d postexposure. Surviving animals exhibited shallow respiration, depression, depressed righting and placement reflexes, excessive salivation, unkempt coats, piloerection, and yellowish-orange urine and mucoid diarrhea stains. All survivors were observed to be emaciated between the fourth and eighth day postexposure. Necropsies of decedents indicated congested lungs, adrenals, and kidneys; mottled livers; irritated GI tracts and peritoneal walls; and fluid-filled stomachs. Necropsies of survivors were unremarkable. | LD_50_ = 1,100–1,760 mg/kg in M rats.; LD_50_ = 1,080–1,220 mg/kg in F rats. | WIL Research (1978)
Acute inhalation lethality | Rats were exposed to a mixture of 2,3- and 3,4-TDA. Study was reported in tabular form with no further details. | LC_50_ >670 ppm. No further details were provided. | Rat inhalation LC_50_ >670 ppm. | Air Products and Chemicals (1976)
Acute inhalation lethality | Rats were exposed to the concentrated vapors of a mixture of 2,3- and 3,4-TDA. No further details were provided. | Maximum time producing no deaths was 8 h. No further details were provided. | Exposure to the concentrated vapors of a TDA mixture is lethal after >8 h of exposure. | Carpenter et al. (1974)
Acute dermal lethality | Rabbits were exposed dermally (abraded and nonabraded skin) to a mixture of 2,3- and 3,4-TDA in a 60% aqueous paste for 24 h and observed for 14 d. Study was reported in tabular form with no further details. | LD_50_ >5,750 mg/kg. No further details were provided. | Dermal LD_50_ >5,750 mg/kg. | Air Products and Chemicals (1976)
Acute dermal lethality | Rabbits were exposed to a mixture of 2,3- and 3,4-TDA on shaved backs for 24 h. No details regarding concentration or occlusion were provided. | LD_50_ (95% CI) = 1,120 (620–2,040) mg/kg. No further details were provided. | Dermal LD_50_ = 1,120 mg/kg. | Carpenter et al. (1974)
Acute dermal irritation | Rabbits were exposed to a mixture of 2,3- and 2,5-TDA (90–95%) and 2,4- and 2,6-TDA (10–15%) applied topically as a 10% solution in Dowanol DPM on abraded or nonabraded skin of the inner surface of ear and abdomen (duration not reported). | Repeated and prolonged contact (not further specified) on inner ear did not cause irritation; on the abdomen, this exposure resulted in slight redness on intact and abraded skin. Body-weight gain was not affected. | A mixture of TDA isomers may be slightly irritating to the skin of rabbits. | Dow Chemical (1983)
Acute dermal irritation | Rabbits were exposed to a mixture of 2,3- and 3,4-TDA on the uncovered skin of the belly. No details regarding concentration or duration of exposure were provided. | Irritation score was 5/10. | A mixture of TDA isomers is moderately irritating to the skin of rabbits. | Carpenter et al. (1974)
Skin sensitization | Guinea pigs were exposed to a mixture of 2,3- and 3,4-TDA. Study was reported in tabular form with no further details. | “Insignificant” sensitization. | A mixture of TDA isomers is not a skin sensitizer in guinea pigs. | Air Products and Chemicals (1976)
Eye irritation | Rabbits were exposed to a mixture of 2,3- and 3,4-TDA in 5% aqueous solution in eye. The study was reported in tabular form with no further details. | No irritation after 72 h. | A diluted mixture of TDAs is not irritating to the rabbit eye. | Air Products and Chemicals (1976)
Eye irritation | Albino rabbits were exposed to undiluted mixtures of 2,3- and 2,5-TDA (90–95%) and 2,4- and 2,6-TDA (10–15%) in eye. | Indications of slight pain, severe conjunctival inflammation, and moderate transient corneal injury were noted. Response was not mitigated by eye washing 30 sec after treatment. Rabbit eyes returned to normal within 7 d. | An undiluted mixture of TDA isomers is irritating to the rabbit eye. | Dow Chemical (1993); Dow Chemical (1983)
Eye irritation | Rabbits were exposed to a mixture of 2,3- and 3,4-TDA in a “suitable vehicle” in eye. | Irritation score was 7/10. | A mixture of TDA isomers is irritating to the rabbit eye. | Carpenter et al. (1974)

CI = confidence interval; F = female(s); GI = gastrointestinal; LC_50_ = median lethal concentration; LD_50_ = median lethal dose; M = male(s); TDA = toluenediamine.

### 2.3.3 Reproductive/Developmental Studies of TDA Mixtures

#### Becci et al. (1983)

Groups of 22 pregnant Sprague Dawley rats were administered o-TDA (a 40:60 mixture of 2,3- and 3,4-TDA) at doses of 0, 10, 30, 100, or 300 mg/kg-day via gavage in corn oil from Gestation Days (GDs) 6–15. Observations were conducted daily for general appearance, behavior, and mortality. Body weights of the dams were recorded on GDs 0, 6, 9, 12, 15, and 20. On GD 20, all dams were sacrificed, and uterine contents were removed and examined. One-half of the fetuses were examined for soft-tissue anomalies and the remaining fetuses were examined for skeletal anomalies. No treatment-related effects on appearance or behavior were observed in treated dams, and all dams survived the duration of the study. There was a statistically significant decrease in weight gain (−20%) during gestation for treated dams receiving 300 mg/kg-day compared with controls. No significant differences in the number of live fetuses, implantation sites, or resorption sites were indicated. Fetal effects indicative of developmental delay included significant reductions in fetal body weight (−18%) in the 300-mg/kg-day group and significant increases in skeletal variations per litter (missing sternebrae at 300 mg/kg-day and incomplete ossification of vertebrae at 100 and 300 mg/kg-day), compared with controls. No exposure-related skeletal or soft-tissue malformations were observed. No maternal or developmental effects were seen at ≤30 mg/kg-day.

Additionally, groups of 15 pregnant female Dutch belted rabbits were exposed to o-TDA at doses of 0, 3, 10, 30, or 100 mg/kg-day via gavage in corn oil from GDs 6–18. Observations were conducted daily for general appearance, behavior, and mortality. Body weights of the does were recorded on GDs 0, 6, 9, 12, 15, 18, and 29. On GD 29, all does were sacrificed, and uterine contents were removed and examined. All the fetuses were examined for both soft-tissue and skeletal anomalies. Appearance and behavior of does were unaffected by treatment. All does survived the duration of the study. Body-weight gain during gestation was significantly decreased (−60%) in treated does receiving 100 mg/kg-day compared with controls. Other observations at this dose included a significant 2.5-fold increase in the incidence of resorptions, a 16% decrease in the mean number of live fetuses per doe (reported as statistically significant in the text, but not in the table showing the data), and a significant 22% decrease in fetal body weight. No exposure-related skeletal or soft-tissue malformations or variations were observed. No maternal or developmental effects were seen at ≤30 mg/kg-day.

#### BASF (2010)

In an OECD 421 reproductive/developmental (R/D) study available only as an industry-submitted summary, groups of male and female Wistar rats (10/sex/group) were administered o-TDA (45:50 mixture of 2,3- and 3,4-TDA) at doses of 0, 10, 50, or 250 mg/kg-day via gavage (vehicle not reported) from premating through mating (males, at least 28 days) or premating through Postnatal Day (PND) 4 (up to 60 days for females). The pups were sacrificed and examined on PND 4 (endpoints examined at sacrifice were not reported). The available summary reported only “the most relevant results”; no statistics were provided, and the summary did not include the magnitude/incidence for many of the findings.

Clinical signs of toxicity (reduced activity, eyelid drop, salivation, and/or piloerection) were observed in males and dams at ≥50 mg/kg-day. Decreased food consumption was observed during premating in males at 250 mg/kg-day and females at ≥50 mg/kg-day; decreased food consumption was also observed in dams during gestation at 250 mg/kg-day. Body-weight gain was decreased throughout the study in high-dose males, with a decreased terminal body weight compared with controls (magnitude not reported). Decreased body weight and body-weight gains were observed during premating and gestation in dams at 250 mg/kg-day, with a decreased terminal body weight compared with controls (magnitude not reported). In males, a decrease in the number of spermatids/g testis was reported at 250 mg/kg-day; however, the study summary did not indicate whether decreased fertility was observed. Reproductive effects observed in high-dose dams included a 39% decrease in the number of implantation sites compared with controls, a 27.4% post implantation loss (control value not reported), and a 42% decrease in the number of delivered pups/litter. In offspring, a decreased viability index of 91% was observed at 250 mg/kg-day (viability index in controls was not reported). No adverse effects were noted in males or dams administered 10 mg/kg-day.

### 2.3.4 Mode-of-Action/Mechanistic Studies

Mechanistic data for 2,3-TDA are limited. Following a single i.p. injection of 0, 10, 20, or 40 mg/kg 2,3-TDA, CYP1A, CYP1A2, and 7-ethoxyresorufin O-deethylation levels in rat liver were elevated in a dose-dependent fashion; significant elevations in 7-methoxyresorufin O-demethylation were only observed at the highest dose (Cheung et al., 1996). In vitro, 2,3-TDA was able to bind to the rat cytosolic aromatic hydrocarbon receptor; the median effective concentration for 2,3,7,8-tetrachlorodibenzo-p-dioxin displacement was 1.5 × 10^−5^ M (Cheung et al., 1996).