# APPENDIX E REFERENCES

ACGIH (American Conference of Governmental Industrial Hygienists). (2020). 2020 TLVs and BEIs: Based on the documentation of the threshold limit values for chemical substances and physical agents & biological exposure indices. Cincinnati, OH.
Adam, M. (1985). Evaluation of mutagenicity of some aromatic amines, used as hair dyes, by chromosomal aberration tests in vivo. Genetica Polonica 26: 109–116.
Air Products and Chemicals (Air Products and Chemicals Inc.). (1976). Toxicity data on toluenediamine with attachments prepared by Air Prods and Chems Inc. (EPA/OTS: Doc #878213786). Wilmington, DE: E.I. Dupont Denemours & Co. Inc.
ATSDR (Agency for Toxic Substances and Disease Registry). (2018). Minimal risk levels (MRLs). June 2018. Atlanta, GA: Agency for Toxic Substances and Disease Registry (ATSDR).
Bajot, F; Cronin, MT; Roberts, DW; Schultz, TW. (2010). Reactivity and aquatic toxicity of aromatic compounds transformable to quinone-type Michael acceptors. SAR QSAR Environ Res 22: 51–65. 10.1080/1062936X.2010.528449
BASF. (2010). Notice in accordance with section 8(e): results of a reproduction/developmental toxicity screening test in Wistar rats with TDA-vicinals (ortho-TDA); [50% of 4-methyl-o-phenylendiamine (CAS No. 496-72-0), 45% of toluol-2,3-diamine (CAS No. 2687-25-4),1% of 4-methyl-m-phenylendiamrne (CAS No. 95-80-7)] [TSCA Submission]. (8EHQ-0610-18000A. 88100000329). Submitted to the U.S. Environmental Protection Agency under TSCA section 8E.
Becci, PJ; Reagan, EL; Knickerbocker, MJ; Barbee, SJ; Wedig, JH. (1983). Teratogenesis study of o-toluenediamine in rats and rabbits. Toxicol Appl Pharmacol 71: 323–329. 10.1016/0041-008X(83)90019-4 6658784
Bogajewski, J; Bogajewska, G. (1982). Comparison of determinations of chromosomal aberrations in anaphases and metaphases. Mutat Res 173: 173–174.
Bornatowicz, N. (1986). Two-generation fertility study with p-toluyenediamine sulphate in rats. Seibersdorf.
Bums, LA; Bradley, SG; White, KL; McCay, JA; Fuchs, BA; Stern, M; Brown, RD; Musgrove, DL; Holsapple, MP; Luster, MI; Munson, AE. (1994). Immunotoxicity of 2,4-diaminotoluene in female B6C3F1 mice. Drug Chem Toxicol 17: 401–436. 10.3109/01480549409017865 7988388
CalEPA (California Environmental Protection Agency). (2009). Technical support document for cancer potency factors 2009. Sacramento, CA: Office of Environmental Health Hazard Assessment, Air Toxics Hot Spots Program. https://oehha.ca.gov/air/crnr/technical-support-document-cancer-potency-factors-2009
CalEPA (California Environmental Protection Agency). (2011a). Air Toxics Hot Spots program technical support document for cancer potencies. Appendix B. Chemical-specific summaries of the information used to derive unit risk and cancer potency values. Updated 2011. Sacramento, CA: Office of Environmental Health Hazard Assessment. https://oehha.ca.gov/air/crnr/technical-support-document-cancer-potency-factors-2009
CalEPA (California Environmental Protection Agency). (2011b). Hot spots unit risk and cancer potency values. Appendix A. Sacramento, CA: Office of Environmental Health Hazard Assessment. http://standards.nsf.org/apps/group_public/download.php?document_id=19121
CalEPA (California Environmental Protection Agency). (2017). Prop 65: §69502.2(a)(1)(A). Chemicals known to cause cancer and/or reproductive toxicity that are listed under Health and Safety Code section 25249.8 of the California Safe Drinking Water and Toxic Enforcement Act of 1986. Available online
CalEPA (California Environmental Protection Agency). (2019). Consolidated table of OEHHA/ARB approved risk assessment health values (September 19, 2019 ed.). Sacramento, CA: California Air Resources Board. https://www.arb.ca.gov/toxics/healthval/contable.pdf
Carpenter, CP; Weil, CS; Smyth, HF, Jr. (1974). Range-finding toxicity data: List VIII. Toxicol Appl Pharmacol 28: 313–319. 10.1016/0041-008x(74)90018-0 4854023
Cartolano, AR. (2005). Toluenediamine [Encyclopedia]. In JI Kroschwitz; A Seidel (Eds.), Kirk-Othmer encyclopedia of chemical technology. Hoboken, NJ: Wiley-Interscience. 10.1002/0471238961.0409011320151905.a01.pub2
Charles River Laboratories (Charles River Laboratories International Inc.). (2010). Toxicokinetics of [14]C toluene-2,5-diamine sulfate following a single oral administration to Sprague-Dawley rats. (Study Number 420782). Senneville, Quebec, Canada.
ChemAxon. (2017). Physico-chemical property predictors. MarvinSketch. Retrieved from https://www.chemaxon.com/products/calculator-plugins/property-predictors/
Cheung, YL; Snelling, J; Mohammed, NN; Gray, TJ; Ioannides, C. (1996). Interaction with the aromatic hydrocarbon receptor, CYP1A induction, and mutagenicity of a series of diaminotoluenes: implications for their carcinogenicity. Toxicol Appl Pharmacol 139: 203–211. 10.1006/taap.1996.0159 8685904
CPDB (Carcinogenic Potency Database). (2011). The carcinogenic potency project: The carcinogenic potency database [Database]: Department of Energy; National Cancer Institute; Environmental Protection Agency; National Institute of Environmental Health Sciences; National Toxicology Program; University of California, Berkeley. Retrieved from https://www.nlm.nih.gov/databases/download/cpdb.html
Criteria Group for Occupational Standards (Criteria Group for Occupational Standards (Sweden)). (2001). Scientific basis for Swedish occupational standards XXII. Consensus report for toluene-2,4-diamine and toluene-2,6-diamine. In Scientific basis for Swedish occupational standards XXII (pp. 25-36). (RISKLINE/2002030006). Stockholm, Sweden: National Institute for Working Life. http://www.inchem.org/documents/kemi/kemi/ah2001_20.pdf
Cunningham, ML; Burka, LT; Matthews, HB. (1989). Metabolism, disposition, and mutagenicity of 2,6-diaminotoluene, a mutagenic noncarcinogen. Drug Metab Dispos 17: 612–617.2575496
Dimitrov, SD; Low, LK; Patlewicz, GY; Kern, PS; Dimitrova, GD; Comber, MH; Phillips, RD; Niemela, J; Bailey, PT; Mekenyan, OG. (2005). Skin sensitization: modeling based on skin metabolism simulation and formation of protein conjugates. Int J Toxicol 24: 189–204. 10.1080/10915810591000631 16126613
Dow Chemical (Dow Chemical Company). (1983). Studies on the effect of Tda and Mda on plankton-daphnia with cover letter. (EPA/OTS Doc #878213711).
Dow Chemical (Dow Chemical Company). (1993). Letter from Dow Chemical Company to USEPA submitting enclosed health and safety studies on toluenediamines with attachments [TSCA Submission]. (EPA/OTS Doc #AR027-026). Midland, MI. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0528874.xhtml
ECHA (European Chemicals Agency). (2008). European Union risk assessment report: 4-methyl-m-phenylenediamine (toluene-2,4-diamine. CAS No: 95-80-7. EINECS No: 202-453-1. (R064_0805_env_hh). Luxembourg: Office for Official Publications of the European Communities. https://echa.europa.eu/documents/10162/c666021a-4985-488e-a066-071cf9513129
ECHA (European Chemicals Agency). (2016). Registered substances [Database]. Helsinki, Finland. Retrieved from http://echa.europa.eu/information-on-chemicals/registered-substances
Grantham, PH; Mohan, L; Benjamin, T; Roller, PP; Miller, JR; Weisburger, EK. (1979). Comparison of the metabolism of 2,4-toluenediamine in rats and mice. J Environ Pathol Toxicol Oncol 3: 149–166.
Hill, RE. (1994). Paratoluenediamine 14 day oral (gavage) toxicity study in the rat. Toxicology Lab, Ltd.
Hill, RE. (1997). Paratoluenediamine 13 week oral (gavage) toxicity study in the rat. UK: Quintiles England Ltd.
HSDB (Hazardous Substances Data Bank). (2013a). 2,3-Diaminotoluene (CASRN: 2687-25-4). Bethesda, MD: U.S. National Library of Medcine.
HSDB (Hazardous Substances Data Bank). (2013b). Toluene-2,4-diamine (CASRN: 95-80-7). Bethesda, MD: U.S. National Library of Medcine.
IARC (International Agency for Research on Cancer). (1987). Overall evaluations of carcinogenicity: An updating of IARC Monographs volumes 1 to 42 [IARC Monograph] (pp. 1–440). Lyon, France. http://monographs.iarc.fr/ENG/Monographs/suppl7/
IARC (International Agency for Research on Cancer). (2018). IARC monographs on the evaluation of carcinogenic risk to humans. http://monographs.iarc.fr/ENG/Monographs/PDFs/index.php
IPCS (International Programme on Chemical Safety). (2020). INCHEM: Chemical safety information from intergovernmental organizations [Database]. Geneva, Switzerland: World Health Organization, Canadian Centre for Occupational Health and Safety. Inter-Organization Programme for the Sound Management of Chemicals. Retrieved from http://www.inchem.org/
Izmerov, NF; Sanotsky, IV; Sidorov, KK. (1982). Toxicometric paramaters of industrial toxic chemicals under single exposure. Moscow, Russia: USSR/SCST/USSR Commission for UNEP, Centre of International Projects.
Kavlock, RJ; Short, RD, Jr; Chernoff, N. (1987). Further evaluation of an in-vivo teratology screen. Teratog Carcinog Mutagen 7: 7–16. 10.1002/tcm.1770070104 2884745
Kirkland, D; Aardema, M; Henderson, L; Müller, L. (2005). Evaluation of the ability of a battery of three in vitro genotoxicity tests to discriminate rodent carcinogens and non-carcinogens: I. Sensitivity, specificity and relative predictivity. Mutat Res 584: 1–256. 10.1016/j.mrgentox.2005.02.004 15979392
Knickerbocker, M; Re, TA; Parent, RA; Wedig, JH. (1980). Teratogenic evaluation of ortho-toluenediamine (o-TDA) in Sprague Dawley rats and Dutch Belted rabbits [Abstract]. Toxicologist 19: A89.
Marchant, CA; Briggs, KA; Long, A. (2008). In silico tools for sharing data and knowledge on toxicity and metabolism: Derek for Windows, Meteor, and Vitic. Toxicol Mech Meth 18: 177–187.
Mekenyan, OG; Dimitrov, SD; Pavlov, TS; Veith, GD. (2004). A systematic approach to simulating metabolism in computational toxicology. I. The TIMES heuristic modelling framework [Review]. Curr Pharm Des 10: 1273–1293. 10.2174/1381612043452596 15078141
NCI (National Cancer Institute). (1979). Bioassay of 2,4-diaminotoluene for possible carcinogenicity. Natl Cancer Inst Carcinog Tech Rep Ser 162: 1–139.12799700
NIOSH (National Institute for Occupational Safety and Health). (2021). NIOSH pocket guide to chemical hazards: Index of chemical abstracts service registry numbers (CAS No.). Available online at http://www.cdc.gov/niosh/npg/npgdcas.html
NLM (National Library of Medicine). (2019). ChemIDplus: National Institutes of Health, U.S. National Library of Medicine. Retrieved from https://chem.nlm.nih.gov/chemidplus/
NTP (National Toxicology Program). (1978). Bioassay of 2,5-toluenediamine sulfate for possible carcinogenicity. Natl Cancer Inst Carcinog Tech Rep Ser 126: 1–123.12799666
NTP (National Toxicology Program). (1980). Bioassay of 2,6-toluenediamine dihydrochloride for possible carcinogenicity (CAS No. 15481-70-6). Natl Toxicol Program Tech Rep Ser 200: 1–123.12778179
NTP (National Toxicology Program). (2016a). 14th Report on carcinogens. Research Triangle Park, NC. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html
NTP (National Toxicology Program). (2016b). Report on carcinogens, 14th edition: 2,4-Diaminotoluene. In Report on Carcinogens, 14th Edition. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/diaminotoluene.pdf
NTP (National Toxicology Program). (2017). NTP technical reports index. Available online at https://ntp.niehs.nih.gov/results/summaries/chronicstudies/index.html
OECD (Organisation for Economic Co-operation and Development). (2017). The OECD QSAR toolbox. Version 4.1. Retrieved from http://www.oecd.org/chemicalsafety/risk-assessment/oecd-qsar-toolbox.htm
OECD (Organisation for Economic Co-operation and Development). (2019). The OECD QSAR toolbox [version 4.3.1]. Retrieved from http://www.oecd.org/chemicalsafety/risk-assessment/oecd-qsar-toolbox.htm
OSHA (Occupational Safety & Health Administration). (2020a). Air contaminants: Occupational safety and health standards for shipyard employment, subpart Z, toxic and hazardous substances. (OSHA Standard 1915.1000). Washington, DC. https://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10286
OSHA (Occupational Safety & Health Administration). (2020b). Table Z-1: Limits for air contaminants. Occupational safety and health standards, subpart Z, toxic and hazardous substances. Available online at http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=9992
Osterburg, I. (1982). p-Toluyenediamine sulfate oral (gavage) teratology study in the rat. Hazelton.
SCCP (Scientific Committee on Consumer Products). (2007). Opinion on toluene-2,5-diamine. (SCCP/1084/07). Brussels, Belgium: European Commission: Health and Consumers Scientific Committees. http://ec.europa.eu/health/ph_risk/committees/04_sccp/docs/sccp_o_108.pdf
SCCS (Scientific Committee on Consumer Safety). (2012). Opinion on toluene-2,5-diamine and its sulfate. (SCCS/1479/12). European Commission: Health and Consumers Scientific Committees. http://ec.europa.eu/health/scientific_committees/consumer_safety/docs/sccs_o_093.pdf
Seidenberg, JM; Anderson, DG; Becker, RA. (1986). Validation of an in vivo developmental toxicity screen in the mouse. Teratog Carcinog Mutagen 6: 361–374. 10.1002/tcm.1770060503 2878502
Selye, H. (1973). Production of perforating duodenal ulcers by 3,4-toluenediamine in the rat. Proc Soc Exp Biol Med 142: 1192–1194. 10.3181/00379727-142-37206 4694822
Takasawa, H; Takashima, R; Hattori, A; Narumi, K; Kawasako, K; Morita, T; Hayashi, M; Hamada, S. (2013). Development of a repeated-dose liver micronucleus assay using adult rats (II): further investigation of 1,2-dimethylhydrazine and 2,6-diaminotoluene. Mutat Res 751: 12–18. 10.1016/j.mrgentox.2012.10.004 23123978
Thysen, B; Bloch, E; Varma, SK. (1985a). Reproductive toxicity of 2,4-toluenediamine in the rat. 2. Spermatogenic and hormonal effects. J Toxicol Environ Health 16: 763–769. 10.1080/15287398509530787 3937900
Thysen, B; Varma, SK; Bloch, E. (1985b). Reproductive toxicity of 2,4-toluenediamine in the rat. 1. Effect on male fertility. J Toxicol Environ Health 16: 753–761. 10.1080/15287398509530786 4093994
Timchalk, C; Smith, FA; Bartels, MJ. (1994). Route-dependent comparative metabolism of [14C]toluene 2,4-diisocyanate and [14C]toluene 2,4-diamine in Fischer 344 rats. Toxicol Appl Pharmacol 124: 181–190. 10.1006/taap.1994.1022 8122263
U.S. EPA (U.S. Environmental Protection Agency). (1988). Recommendations for and documentation of biological values for use in risk assessment [EPA Report]. (EPA/600/6-87/008). Cincinnati, OH. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=34855
U.S. EPA (U.S. Environmental Protection Agency). (1991). Integrated risk information system (IRIS): Chemical assessment summary: 2,4-Diaminotoluene; CASRN 95-80-7. Washington, DC: U.S. Environmental Protection Agency. Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0536_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2005a). Guidelines for carcinogen risk assessment [EPA Report]. (EPA/630/P-03/001F). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3-25-05.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2005b). Provisional peer-reviewed toxicity values for 2,6-toluenediamine (CASRN 823-40-5) [EPA Report]. Cincinnati, OH. https://hhpprtv.ornl.gov/issue_papers/Toluenediamine26.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2011a). Chemical Assessment Clustering Engine (ChemACE) [Database]. Retrieved from https://www.epa.gov/tsca-screening-tools/chemical-assessment-clustering-engine-chemace
U.S. EPA (U.S. Environmental Protection Agency). (2011b). Health effects assessment summary tables (HEAST) for superfund. Available online at https://epa-heast.ornl.gov/heast.php
U.S. EPA (U.S. Environmental Protection Agency). (2011c). Recommended use of body weight 3/4 as the default method in derivation of the oral reference dose. (EPA/100/R-11/0001). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/recommended-use-of-bw34.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2012). Estimation Programs Interface Suite™ for Microsoft® Windows, v 4.11: 1,2-Benzenediamine (CASRN 95-54-5) [Fact Sheet]. Washington, DC. https://www.epa.gov/tsca-screening-tools/epi-suitetm-estimation-program-interface
U.S. EPA (U.S. Environmental Protection Agency). (2013). Provisional peer-reviewed toxicity values for toluene-2,5-diamine (CASRN 95-70-5) and compounds toluene-2,5-diamine sulfate (6369-59-1) [also known as 1,4-benzenediamine-2-methyl sulfate or 2-methylbenzene-1,4-diamine sulfate (615-50-9)], toluene-2,5-diamine dihydrochloride (615-45-2), and toluene-2,5-diamine monohydrochloride (74612-12-7) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Benzenediamine2methylsulfate14.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2015). About the TSCA chemical substance inventory. Download the non-confidential TSCA inventory [Database]. Retrieved from http://www2.epa.gov/tsca-inventory/how-access-tsca-inventory
U.S. EPA (U.S. Environmental Protection Agency). (2017). IRIS carcinogens: §69502.2(a)(1)(E). Chemicals that are identified as “carcinogenic to humans,” “likely to be carcinogenic to humans,” or Group A, B1, or B2 carcinogens in the United States Environmental Protection Agency’s Integrated Risk Information System. Available online
U.S. EPA (U.S. Environmental Protection Agency). (2018). 2018 Edition of the drinking water standards and health advisories [EPA Report]. (EPA/822/F-18/001). Washington, DC: U.S. Environmental Protection Agency, Office of Water. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2019). CompTox Chemicals Dashboard [Database]. Research Triangle Park, NC. Retrieved from https://comptox.epa.gov/dashboard
U.S. EPA (U.S. Environmental Protection Agency). (2020a). Integrated risk information system. IRIS assessments [Database]. Washington, DC. Retrieved from http://www.epa.gov/iris/
U.S. EPA (U.S. Environmental Protection Agency). (2020b). Provisional peer-reviewed toxicity values (PPRTVs) for superfund: Derivation support documents [Database]. Washington, DC. Retrieved from https://www.epa.gov/pprtv
Varma, SK; Bloch, E; Gondos, B; Rossi, V; Gunsalus, GL; Thysen, B. (1988). Reproductive toxicity of 2,4-toluenediamine in the rat 3 Effects on androgen-binding protein levels, selected seminiferous tubule characteristics, and spermatogenesis. J Toxicol Environ Health 25: 435–451. 10.1080/15287398809531222 3199457
Wang, NC; Zhao, QJ; Wesselkamper, SC; Lambert, JC; Petersen, D; Hess-Wilson, JK. (2012). Application of computational toxicological approaches in human health risk assessment. I. A tiered surrogate approach. Regul Toxicol Pharmacol 63: 10–19. 10.1016/j.yrtph.2012.02.006 22369873
Waring, RH; Pheasant, AE. (1975). Some phenolic metabolites of 2, 4-diaminotoluene in the rabbit, rat and guinea-pig. Xenobiotica 6: 257–262. 10.3109/00498257609151635
Weisbrod, D; Stephan, U. (1983). [Studies of the toxic, methaemoglobin-producing and erythrocyte-damaging effects of diaminotoluene after a single administration]. Z Gesamte Hyg 29.
Weisburger, EK; Russfield, AB; Homburger, F; Weisburger, JH; Boger, E; Van Dongen, CG; Chu, KC. (1978). Testing of twenty-one environmental aromatic amines or derivatives for long-term toxicity or carcinogenicity. J Environ Pathol Toxicol 2: 325–356.84039
Wenker, MAM. (2005a). Absorption, distribution, metabolism and excretion of 14C-toluene-2,5-diamine sulphate in the female Wistar Kyoto rat after a single intravenous dose. Wenker, MAM.
Wenker, MAM. (2005b). Absorption, distribution, metabolism and excretion of 14C-toluene-2,5-diamine sulphate in the female Wistar Kyoto rat after a single oral or dermal dose. Wenker, MAM.
Wenker, MAM. (2005c). Pharmacokinetics of 14C-toluene-2,5-diamine sulphate in the female Sprague-Dawley rat after a single oral or dermal dose. Wenker, MAM.
WHO (World Health Organization). (1987). Diaminotoluenes. Environmental health criteria: 74 [WHO EHC] (pp. 3-67). (RISKLINE/1988050043). Geneva, Switzerland: World Health Organization. International Programme on Chemical Safety. http://www.who.int/iris/handle/10665/39601#sthash.qSt5rWMo.dpuf
WIL Research (WIL Research Laboratories). (1978). Initial submission: acute oral toxicity study in rats with two formulae of curing agent y (final report) with cover letter dated 011492. (TSCATS/422747. OTS0535720. Doc #88-920000954). Houston, TX: Shell Oil Company.
Wu, S; Fisher, J; Naciff, J; Laufersweiler, M; Lester, C; Daston, G; Blackburn, K. (2013). Framework for identifying chemicals with structural features associated with the potential to act as developmental or reproductive toxicants. Chem Res Toxicol 26: 1840–1861. 10.1021/tx400226u 24206190