# APPENDIX C RESULTS OF THE SCREENING EVALUATION OF POTENTIAL CARCINOGENICITY

## STEP 1 USE OF AUTOMATED TOOLS TO IDENTIFY STRUCTURAL ANALOGUES WITH CARCINOGENICITY AND/OR GENOTOXICITY DATA

U.S. EPA’s Chemical Assessment Clustering Engine (ChemACE) clustering was performed as described in Appendix B. The cluster containing 2,3-toluenediamine (2,3-TDA; less restrictive approach; Cluster 71) also contains 3,4-toluenediamine (3,4-TDA; an additional target compound being evaluated in a separate Provisional Peer-Reviewed Toxicity Value [PPRTV] document) and 13 structural analogues. The 15 cluster members all contain a benzene ring substituted with one or more amino groups (−NR_2_) and one or more methyl groups (−CH_3_). The methyl groups are present on the ring or the nitrogen substituent (−N(CH_3_)_2_) (see Figure C-1).

Figure C-1 Illustration of Common Fragments in Cluster 71

The Organisation for Economic Co-operation and Development (OECD) Quantitative Structure-Activity Relationship (QSAR) Toolbox Profiler was used to identify structural analogues from the Dice analogue search with carcinogenicity and/or genotoxicity data (see Step 1 methods in Appendix B). This process identified an additional 31 compounds to be considered as potential analogues for 2,3-TDA. Refinement of selection of final analogues is described below.

## STEP 2 ANALOGUE REFINEMENT USING EXPERT JUDGMENT

Expert judgment was applied to refine the initial list of 44 potential analogues based on physicochemical properties; absorption, distribution, metabolism, and excretion (ADME); and mechanisms of toxicity.

Compounds were considered potential analogues if they had (1) one aromatic ring (benzene) substituted with (2) two unsubstituted amines on the ring, in a meta (m)- or para (p)-substitution pattern, (3) a methyl group on the ring, and (4) no other functional group. Such compounds are similar to the target chemical in all attributes except for the proximity of the two amine substituents to one another on the aromatic ring. The closest analogue for 2,3-TDA structurally would be 3,4-TDA because of the similar ortho (o)-substitution pattern; however, 3,4-TDA does not have adequate experimental data for evaluating potential carcinogenicity and was not considered further as an analogue. Simple salts (e.g., hydrochlorides or sulfates) of the m- and p-substituted diamines are also considered as potential analogues.

Of the 44 chemicals identified as potential analogues by ChemACE clustering and the OECD Toolbox analogue selection tool (Dice), 36 were not selected for further review. Common rationales for not selecting these chemicals included the presence of polycyclic aromatics or ring systems other than toluene; lack of two amine substituents; occurrence of functional groups not present in the target chemicals (e.g., phenols, halogens, carboxylic acids); N-alkyl-substituted amines and acetamide derivatives of aromatic amines. In addition, nitro amines and dinitro compounds were not selected. Each of these attributes introduce significant differences in bioavailability, reactivity, and applicable metabolic pathways relative to 2,3-TDA. Additionally, ar-methyl-1,3-benzenediamine (CASRN 25376-45-8) was not selected for further review because it can exist as a mixture of two TDA isomers, in which the location of the methyl on the aromatic ring is not defined.

The remaining eight possible analogues for 2,3-TDA are listed in Table C-1. The existence of a cancer risk estimate and/or a weight-of-evidence (WOE) determination for cancer is indicated for each analogue. Compounds are grouped with their respective simple salts, which were identified by Dice only. Salts did not cluster with free acids in ChemACE because it is fragment-based; therefore, salts and free acids have different fragments and will not cluster without special adjustment (i.e., modify the Simplified Molecular Input Line Entry System [SMILES] being clustered so that representative free acid structures are entered for salts). The analogue results from Dice are based on SMILES arbitrary target specification (SMARTS) substructure searching, allowing for identification of both free acid and respective salt analogues.

Table C-1 Summary of Cancer Assessment Information for Analogues of 2,3-Toluenediamine (CASRN 2687-25-4)

Analogue Name (CASRN) | Cancer Risk Estimates (if available) | WOE Determinations
2,6-TDA (823-40-5)^a,^ ^b^; 2,6-TDA dihydrochloride (15481-70-6)^b^ | None | U.S. EPA (2005b)―inadequate information
2,5-TDA (95-70-5)^a,^ ^b^; 2,5-TDA dihydrochloride (615-45-2)^b^; 2,5-TDA sulfate (6369-59-1 and 615-50-9)^b^ | U.S. EPA (2013)―screening p-OSF | U.S. EPA (2013)―suggestive; IARC (1987)―not classifiable
2,4-TDA (95-80-7)^a,^ ^b^; 2,4-TDA dihydrochloride (636-23-7)^b^ | CalEPA (2011a)―OSF, IUR | IARC (1987)―possibly; NTP (2016b)―reasonably anticipated; CalEPA (2011a)―known
2,3-Dimethylbenzene-1,4-diamine (5306-96-7)^b^ | None | None

a Found by ChemACE.

b Found by Dice.

IUR = inhalation unit risk; OSF = oral slope factor; p-OSF = provisional oral slope factor; TDA = toluenediamine; WOE = weight of evidence.

2,3-Dimethylbenzene-1,4-diamine, which lacks a cancer risk estimate or WOE determination (highlighted in gray in Table C-1), was not further considered as a potential analogue for the screening evaluation of potential carcinogenicity of 2,3-TDA. Compounds selected for further consideration were 2,4-, 2,5-, and 2,6-TDA and their simple salts.

## STEP 3 COMPARISON OF THE EXPERIMENTAL GENOTOXICITY DATA FOR 2,3-TDA AND ANALOGUES

The limited genotoxicity data available for 2,3-TDA are described in detail in the “Other Data” section in the main body of this report. The data indicate that 2,3-TDA is a weak mutagen but does not cause chromosomal aberrations (CAs) following in vivo exposure. A summary of the genotoxicity data for the structural analogues, 2,4-, 2,5-, and 2,6-TDA, is provided below for comparative purposes.

2,4-, 2,5-, and 2,6-TDA are mutagenic to Salmonella typhimurium in the presence of metabolic activation (U.S. EPA, 2013; ECHA, 2008; U.S. EPA, 2005b). Sex-linked recessive mutations were observed in Drosophila melanogaster exposed to 2,4-TDA (ECHA, 2008). However, 2,4-, 2,5-, and 2,6-TDA were generally nonmutagenic to mammalian cells in vitro or in vivo (U.S. EPA, 2013; ECHA, 2008; U.S. EPA, 2005b).

2,4-, 2,5-, and 2,6-TDA show evidence of in vitro clastogenicity in mammalian cells, both with and without metabolic activity. CAs were induced by 2,4- and 2,5-TDA, sister chromatid exchanges (SCEs) were induced by 2,4-TDA, and micronuclei (MN) were induced by 2,6-TDA (U.S. EPA, 2013; ECHA, 2008; U.S. EPA, 2005b). Induction of MN in bone marrow or hepatocytes was generally not observed following in vivo exposure to 2,4-, 2,5-, or 2,6-TDA. However, weak induction of MN in bone marrow following exposure to 2,4- or 2,6-TDA was reported in some studies (Takasawa et al., 2013; U.S. EPA, 2013; ECHA, 2008; U.S. EPA, 2005b).

The majority of in vitro studies indicate that 2,4-, 2,5-, and 2,6-TDA are capable of damaging mammalian deoxyribonucleic acid (DNA). Results were most consistent with 2,4-TDA, which induced DNA damage and/or unscheduled DNA synthesis (UDS) in human skin fibroblasts, human hepatocytes, and primary rat hepatocytes, and formed DNA adducts in rat hepatocytes and purified calf thymus DNA (ECHA, 2008). 2,5-TDA also induced DNA damage in rat and hamster hepatocytes (U.S. EPA, 2013). UDS was observed in primary cultured human hepatocytes exposed to 2,6-TDA, but not primary rat hepatocytes (U.S. EPA, 2005b). Low levels of covalent binding to DNA were observed for 2,6-TDA (U.S. EPA, 2005b). DNA strand breaks and UDS were consistently reported in rodents following in vivo exposure to 2,4-TDA (ECHA, 2008), but results in rodents exposed to 2,5- or 2,6-TDA were mixed (U.S. EPA, 2013, 2005b). DNA adducts were observed in multiple organs following in vivo exposure to 2,4-, but not 2,6-TDA (ECHA, 2008; U.S. EPA, 2005b). 2,5- and 2,6-TDA induced cell transformation in hamster embryo cells (U.S. EPA, 2013, 2005b).

In summary, 2,3-TDA and its analogues show some evidence of mutagenicity in bacterial systems with metabolic activation. Additionally, 2,4-, 2,5-, and 2,6-TDA display potential for causing clastogenic effects and DNA damage in mammalian cells under certain conditions. No genotoxic effects were reported for 2,3-TDA in studies using mice but the evidence is too limited to adequately assess its genotoxic potential.

## STEP 4 TOXICOKINETICS OF 2,3-TDA AND ANALOGUES

The toxicokinetics of 3,4-, 2,4-, 2,5-, and 2,6-TDA are briefly described in Table C-2 (see additional information in Table A-3). Experimental data indicate that 2,4-, 2,5-, and 2,6-TDA are rapidly absorbed following oral exposure and excreted in the urine (see Table A-3). The primary metabolic pathways for 2,4-, 2,5-, and 2,6-TDA include acetylation of the amino groups and ring hydroxylation with some evidence of oxidation of the methyl group (see Table A-3). No toxicokinetic data are available for 2,3-TDA, but similar metabolic pathways are expected for the target compound based on a comparative in silico metabolism analysis (see section on “Metabolic Analogues” in Appendix A and Appendix D for additional details).

Table C-2 Summary of Toxicokinetic Data for 2,3-Toluenediamine (CASRN 2687-25-4) and Analogues

Compound | Absorption, Distribution, Excretion | Metabolism | References
2,3-TDA | ND | ND | NA
2,4-TDA | - Rapid and extensive absorption; - Wide distribution; - Primarily excreted in urine, with small amounts in feces | - Primary pathways include acetylation of the amino groups and ring hydroxylation; - Primary urinary metabolites: 3-hydroxy-4-acetylamino-2-aminotoluene, 5-hydroxy-2,4-diaminotoluene, and 5-hydroxy-4-acetylamino-2-aminotoluene | Timchalk et al. (1994); Grantham et al. (1979); Waring and Pheasant (1975)
2,6-TDA | - Rapid and extensive absorption; - Wide distribution; - Primarily excreted in urine, with small amounts in feces | - Primary pathways include acetylation of the amino groups and ring hydroxylation; - Primary urinary metabolites: 3-hydroxy-2,6-toluenediamine, 5-hydroxy-2-acetylamino-6-aminotoluene, 2-acetylamino-6-aminotoluene, and 2,6-diacetylamino-toluene | Cunningham et al. (1989)
2,5-TDA | - Rapid and extensive absorption; - Wide distribution; - Primarily excreted in urine, with small amounts in feces | - Primary pathways include acetylation of the amino groups and ring hydroxylation; - Primary urinary metabolites: N,N′-diacetyl-toluene-2,5-diamine | Wenker (2005a), Wenker (2005b), Wenker (2005c), and Charles River Laboratories (2010) as cited in SCCS (2012), pages 50–52 and 56–57

NA = not applicable; ND = no data; TDA = toluenediamine.

## STEP 5 CARCINOGENICITY OF 2,3-TDA ANALOGUES AND MODE-OF-ACTION DISCUSSION

U.S. EPA cancer WOE descriptors for 2,3-TDA and its analogue compounds are shown in Table C-3. As noted in the main PPRTV document, there is inadequate information to assess the carcinogenic potential of 2,3-TDA. The analogue 2,5-TDA is characterized by U.S. EPA as having evidence of carcinogenic potential. Under the 2005 Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005a), there is “Suggestive Evidence of Carcinogenic Potential” for 2,5-TDA (U.S. EPA, 2013). The U.S. EPA has not assessed the potential carcinogenicity of 2,4-TDA (U.S. EPA, 1991); however, this compound is listed as a carcinogen by CalEPA (2011b), considered possibly carcinogenic to humans by IARC (1987), and reasonably anticipated to be a human carcinogen by NTP (2016b). The U.S. EPA determined that there is “Inadequate Information to Assess Carcinogenic Potential” for 2,6-TDA (U.S. EPA, 2005b). Oral slope factor (OSF) values varied by an order of magnitude, with the highest potency value calculated for 2,4-TDA (4 × 10^0^ [mg/kg-day]^−1^) (CalEPA, 2011b) and the lowest (screening) potency value for 2,5-TDA (1.8 × 10^−1^ [mg/kg-day]^−1^ as a sulfate) (U.S. EPA, 2013). Exposure-related increases were observed in liver tumors in male and female rats and female mice, subcutaneous fibromas in male rats, mammary tumors in female rats, and lymphoma in female mice following dietary 2,4-TDA exposure (NTP, 2016b; CalEPA, 2011b; IARC, 1987). Testicular tumors were observed in male rats and lung tumors were observed in female mice following dietary exposure to 2,5-TDA (U.S. EPA, 2013). Potential carcinogenic effects of 2,6-TDA were evaluated in rats and mice in 2-year feeding studies (U.S. EPA, 2005b; NTP, 1980). Dose-related trends for increased incidence of hepatocellular carcinomas and islet-cell adenomas of the pancreas were observed in male rats, a slight increase in vascular neoplasm of the spleen and liver and a significant trend in increased lymphomas were observed in male mice, and a significant trend for increased hepatocellular carcinomas was reported in female mice (U.S. EPA, 2005b). The study authors did not consider the neoplastic lesions observed with exposure to 2,6-TDA to be treatment-related due to the absence of statistically significant effects in any treatment group compared to controls, but it was unclear whether exposure levels were adequate to assess carcinogenic potential (U.S. EPA, 2005b). The carcinogenic mode of action (MOA) has not been established for 2,4- or 2,5-TDA, although both compounds (along with 2,6-TDA and the target compound, 2,3-TDA) exhibit some evidence of genotoxicity (see “Step 3. Comparison of the Experimental Genotoxicity Data for 2,3-TDA and Analogues” above for more information).

Table C-3 Comparison of Available Oral Carcinogenicity Data for 2,3-Toluenediamine (CASRN 2687-25-4) and Analogues

Type of Data | 2,3-TDA CASRN 2687-25-4 | 2,4-TDA CASRN 95-80-7 | 2,6-TDA CASRN 823-40-5 | 2,5-TDA CASRN 95-70-5
Role | Target | Analogue | Analogue | Analogue
Structure | structure diagram | structure diagram | structure diagram | structure diagram
U.S. EPA WOE characterization | “Inadequate Information to Assess Carcinogenic Potential” (see Table 6) | NA^a^ | “Inadequate Information to Assess Carcinogenic Potential” | “Suggestive Evidence of Carcinogenic Potential”
Oral slope factor (mg/kg-d)^−1^ | NA | 4 × 10^0^ ^b^ | ND | Screening p-OSF: 1 × 10^−1^ (as sulfate); screening p-OSF: 1.8 × 10^−1^ (as free base)
Data set(s) used for slope factor derivation | NA | NTP (1978): mammary gland tumors in female F344 rats | NTP (1980) studies were considered insufficient to assess carcinogenic potential; results were not considered treatment related, but doses were too low, and a maximum tolerated dose was not achieved | NTP (1978): interstitial-cell tumors of the testis in male F344 rats
Other tumors observed in animal bioassays | NA | Liver tumors in rats and mice; subcutaneous fibroma in male rats; lymphoma in female mice | NA | Lung tumors in female mice
Study doses (mg/kg-d) | NA | 0, 3.2, 7.0 (M); 0, 3.95, 8.55 (F) | NA | Adjusted daily dose: 0, 47, 158 (M); 0, 55, 183 (F)
Route (method) | NA | Diet | Diet | Diet
Duration | NA | 103 wk | 2 yr | 78 wk
POD type | NA | BMDL_10_ | NA | BMDL_10_ (HED)
Source | NA | CalEPA (2011a); CalEPA (2009) | U.S. EPA (2005b) | U.S. EPA (2013)

a There is no U.S. EPA WOE descriptor for 2,4-TDA; however, this compound is listed as a carcinogen by CalEPA (2011a), considered possibly carcinogenic to humans by IARC (1987), and reasonably anticipated to be a human carcinogen by NTP (2016b).

b OSF derived by CalEPA (2011a).

BMDL_10_ = 10% benchmark dose lower confidence limit; F = female(s); HED = human equivalent dose; M = male(s); NA = not applicable; ND = no data; OSF = oral slope factor; POD = point of departure; p-OSF = provisional oral slope factor; TDA = toluenediamine; WOE = weight of evidence.

## STEP 6 STRUCTURAL ALERTS AND STRUCTURE-ACTIVITY RELATIONSHIP PREDICTIONS FOR 2,3-TDA AND ANALOGUES

Structural alerts (SAs) and predictions for genotoxicity and carcinogenicity were identified using computational tools as described in Appendix B. The model results for 2,3-TDA and its analogue compounds are shown in Table C-4. Concerns for carcinogenicity and/or mutagenicity of 2,3-TDA and its analogues were indicated by several models within each predictive tool (see Table C-4). Table C-5 provides a list of the specific SAs that underlie the findings of a concern for carcinogenicity or mutagenicity in Table C-4.

OECD QSAR Toolbox models showed a concern for mutagenicity, CAs, MN, and protein binding for 2,3-TDA and all analogues based on SAs (see Table C-4 and Table C-5). The ToxRead and VEGA models also indicated a concern for mutagenicity for 2,3-TDA and all analogues. The Toxtree tool indicated a concern for 2,4- and 2,5-TDA mutagenicity in S. typhimurium TA100 but indicated that 2,3- and 2,6-TDA were unlikely to be mutagenic in S. typhimurium TA100. The Toxtree results for 2,3- and 2,6-TDA are inconsistent with positive experimental data (see “Step 3. Comparison of the Experimental Genotoxicity Data for 2,3-TDA and Analogues” above for more information) and the results of the other QSAR models.

Table C-4 Heat Map Illustrating the Structural Alert and SAR Prediction Results for 2,3-Toluenediamine (CASRN 2687-25-4) and Analogues

Tool | | Model^a^ | 2,3-TDA | 2,6-TDA | 2,6-TDA dihydrochloride | 2,5-TDA | 2,5-TDA dihydrochloride | 2,5-TDA sulfate | 2,4-TDA | 2,4-TDA dihydrochloride
Mutagenicity/genotoxicity alerts
OECD QSAR Toolbox | | DNA alerts for Ames by OASIS
OECD QSAR Toolbox | | DNA alerts for CA and MNT by OASIS
OECD QSAR Toolbox | | In vitro mutagenicity (Ames test) alerts by ISS
OECD QSAR Toolbox | | In vivo mutagenicity (micronucleus) alerts by ISS
OECD QSAR Toolbox | | Protein binding alerts for CA by OASIS
ToxRead | | ToxRead (mutagenicity)
VEGA | | Mutagenicity (Ames test) CONSENSUS model―assessment
VEGA | | Mutagenicity (Ames test) model (CAESAR)―assessment
VEGA | | Mutagenicity (Ames test) model (SARpy/IRFMN)―assessment
VEGA | | Mutagenicity (Ames test) model (ISS)―assessment
VEGA | | Mutagenicity (Ames test) model (k-NN/read-across)―assessment
Toxtree | | Potential Salmonella typhimurium TA100 mutagen based on QSAR
Carcinogenicity alerts
OECD QSAR Toolbox | | Carcinogenicity (genotoxicity and nongenotoxicity) alerts by ISS
OncoLogic | | OncoLogic (prediction of the carcinogenic potential of the chemical)
VEGA | | Carcinogenicity model (CAESAR)―assessment
VEGA | | Carcinogenicity model (ISS)―assessment
VEGA | | Carcinogenicity model (IRFMN/ANTARES)―assessment
VEGA | | Carcinogenicity model (IRFMN/ISSCAN-CGX)―assessment
Toxtree | | Potential carcinogen based on QSAR
Toxtree | | Nongenotoxic carcinogenicity
Combined alerts
ToxAlerts | | Aromatic amine (general) (for genotoxic carcinogenicity, mutagenicity)
ToxAlerts | | Aromatic amine (specific) (for genotoxic carcinogenicity, mutagenicity)
ToxAlerts | | Aromatic amines (for genotoxic carcinogenicity, mutagenicity)
ToxAlerts | | Primary and secondary aromatic amines (for genotoxic carcinogenicity, mutagenicity)
ToxAlerts | | Primary ar. amine, hydroxyl amine and its derived esters or amine generating group (genotoxicity, carcinogenicity, mutagenicity)
Toxtree | | Structural alert for genotoxic carcinogenicity
| Model results or alerts indicating no concern for carcinogenicity/mutagenicity.
| Model results outside the applicability domain for carcinogenicity/mutagenicity.
| Model results or alerts indicating concern for carcinogenicity/mutagenicity.

a All tools and models described in Appendix B were used. Models with results or alerts are presented in the heat map (models without results were omitted).

ANTARES = Alternative Non-Testing Methods Assessed for REACH Substances; CA = chromosomal aberration; CAESAR = Computer-Assisted Evaluation of industrial chemical Substances According to Regulations; CONSENSUS = consensus assessment based on multiple models (CAESAR, SARpy, ISS, and k-NN); DNA = deoxyribonucleic acid; IRFMN = Istituto di Ricerche Farmacologiche Mario Negri; ISS = Istituto Superiore di Sanità; ISSCAN-CGX = Istituto Superiore di Sanità Chemical Carcinogen; k-NN = k-nearest neighbor; OECD = Organisation for Economic Co-operation and Development; SAR = structure-activity relationship; QSAR = quantitative structure-activity relationship; VEGA = Virtual models for property Evaluation of chemicals within a Global Architecture.

Table C-5 SAs for 2,3-Toluenediamine (CASRN 2687-25-4) and Analogues

SA | Tools | Compounds
Aromatic amine | OncoLogic | 2,3-TDA;; 2,4-TDA;; 2,4-TDA dihydrochloride;; 2,5-TDA;; 2,5-TDA dihydrochloride;; 2,5-TDA sulfate;; 2,6-TDA;; 2,6-TDA dihydrochloride^a^
Aromatic amine | ToxAlerts | 2,3-TDA;; 2,4-TDA;; 2,4-TDA dihydrochloride;; 2,5-TDA;; 2,5-TDA dihydrochloride;; 2,5-TDA sulfate;; 2,6-TDA;; 2,6-TDA dihydrochloride^a^
Primary aromatic amine, hydroxyl amine, and its derived esters | Toxtree | 2,3-TDA;; 2,4-TDA;; 2,4-TDA dihydrochloride;; 2,5-TDA;; 2,5-TDA dihydrochloride;; 2,5-TDA sulfate;; 2,6-TDA;; 2,6-TDA dihydrochloride^a^
Primary aromatic amine, hydroxyl amine, and its derived esters | OECD QSAR Toolbox | 2,3-TDA;; 2,4-TDA;; 2,4-TDA dihydrochloride;; 2,5-TDA;; 2,5-TDA dihydrochloride;; 2,5-TDA sulfate;; 2,6-TDA;; 2,6-TDA dihydrochloride^a^
Primary aromatic amine, hydroxyl amine, and its derived esters or amine generating group | ToxAlerts | 2,3-TDA;; 2,4-TDA;; 2,4-TDA dihydrochloride;; 2,5-TDA;; 2,5-TDA dihydrochloride;; 2,5-TDA sulfate;; 2,6-TDA;; 2,6-TDA dihydrochloride^a^
Substituted anilines | OECD QSAR Toolbox | 2,3-TDA;; 2,4-TDA;; 2,4-TDA dihydrochloride;; 2,5-TDA;; 2,5-TDA dihydrochloride;; 2,5-TDA sulfate;; 2,6-TDA;; 2,6-TDA dihydrochloride^a^
Single ring-substituted primary aromatic amines | OECD QSAR Toolbox | 2,3-TDA;; 2,4-TDA;; 2,4-TDA dihydrochloride;; 2,5-TDA;; 2,5-TDA dihydrochloride;; 2,5-TDA sulfate;; 2,6-TDA;; 2,6-TDA dihydrochloride^a^

a The SA in OncoLogic for 2,6-TDA dihydrochloride was reported as “marginal.”

OECD = Organisation for Economic Co-operation and Development; QSAR = quantitative structure-activity relationship; SA = structural alert; TDA = toluenediamine.

OECD QSAR Toolbox models showed a concern for carcinogenicity for 2,3-TDA and all analogues based on SAs (see Table C-4 and Table C-5). The level of carcinogenicity concern in OncoLogic for 2,3-TDA was “high-moderate” based on structure-activity relationship (SAR) analysis only (aromatic amine with amino groups ortho to one another). OncoLogic indicated the level of concern for carcinogenicity as “moderate” for 2,4-TDA based on animal carcinogenicity data and SAR analysis (aromatic amine with amino groups meta to one another). The level of carcinogenicity concern in OncoLogic for 2,6-TDA, 2,5-TDA, 2,5-TDA hydrochloride, 2,5-TDA sulfate and 2,4-TDA dihydrochloride was “moderate” based on SAR analysis only (aromatic amine with amino groups meta or para to one another). OncoLogic reported a “marginal” level of concern for 2,6-TDA dihydrochloride (shown as no results for model in Table C-4) based on a lack of evidence of carcinogenicity from animal studies and SAR analysis (aromatic amine with amino groups meta to one another). VEGA showed concern for carcinogenicity of 2,3-TDA using the CAESAR and ISS models (no data for the IRFMN/ANTARES or IRFMN/ISSCAN-CGX models). All four VEGA models showed concern for carcinogenicity for 2,4-TDA and 2,4-TDA dihydrochloride. Carcinogenicity models in VEGA produced inconsistent results for 2,5- and 2,6-TDA (and their salts). While the CAESAR model showed concern for both compounds (and their salts), the ISS model showed concern only for 2,5-TDA (and its salts), and the IRFMN/ISSCAN-CGX model did not show concern for either compound (or their salts). There were no data for the IRFMN/ANTARES model for 2,5- or 2,6-TDA (or their salts). The Toxtree tool indicated that 2,3-, 2,4-, and 2,6-TDA were potential carcinogens based on QSAR, but 2,5-TDA was not. The Toxtree tool showed there was no concern for nongenotoxic carcinogenicity for 2,3-TDA or any of its analogues.

The ToxAlerts tool showed a concern for genotoxic carcinogenicity and/or mutagenicity for 2,3-TDA and all analogues based on various SAs (see Table C-4 and Table C-5). The Toxtree models also suggest a concern for genotoxic carcinogenicity for 2,3-TDA and all analogues based on SAs.

In general, SAR predictions indicate a concern for genotoxicity and carcinogenicity for 2,3-TDA and TDA analogues across several software systems evaluated. Moreover, a clear pattern or relationship between the position of the amino groups (2,3-TDA is a o- isomer, 2,5- is a p- isomer, and 2,4- and 2,6- are m- isomers) and potential differences in SAR predictions are not apparent for the TDA compounds. Previous SAR evaluations have suggested enhanced chemical reactivity for the o- and p-substituted aromatic amines due to quinone formation (Bajot et al., 2010). However, based on the available experimental and in silico data discussed above, the influence of the position of the amino groups on the potential genotoxicity and carcinogenicity of the TDA compounds is unclear.

## STEP 7 EVIDENCE INTEGRATION FOR SCREENING EVALUATION OF 2,3-TDA CARCINOGENICITY

Table C-6 presents the data for multiple lines of evidence pertinent to the screening evaluation of the carcinogenic potential of 2,3-TDA.

Table C-6 Integration of Evidence for 2,3-Toluenediamine (CASRN 2687-25-4) and Analogues

Evidence Stream | 2,3-TDA CASRN 2687-25-4 | 2,4-TDA CASRN 95-80-7 | 2,6-TDA CASRN 823-40-5 | 2,5-TDA CASRN 95-70-5
Role | Target | Analogue | Analogue | Analogue
Structure | structure diagram | structure diagram | structure diagram | structure diagram
Analogue selection and evaluation (see Steps 1 and 2) | Target compound: contains (1) one aromatic ring (benzene) substituted with (2) two unsubstituted amines on the ring, in an o-substitution pattern, (3) a methyl group on the ring, and (4) no other functional group | Isomer: contains (1) one aromatic ring (benzene) substituted with (2) two unsubstituted amines on the ring, in a m-substitution pattern, (3) a methyl group on the ring, and (4) no other functional group | Isomer: contains (1) one aromatic ring (benzene) substituted with (2) two unsubstituted amines on the ring, in a m-substitution pattern, (3) a methyl group on the ring, and (4) no other functional group | Isomer: contains (1) one aromatic ring (benzene) substituted with (2) two unsubstituted amines on the ring, in a p-substitution pattern, (3) a methyl group on the ring, and (4) no other functional group
Experimental genotoxicity data (see Step 3) | Weak mutagen in Salmonella; did not induce CAs in vivo | Mutagenic in Salmonella; clastogenic in mammalian cells; DNA damaging in mammalian cells in vitro and in vivo; forms DNA adducts in vivo | Mutagenic in Salmonella; clastogenic in mammalian cells; inconsistent evidence for DNA damage in mammalian cells in vitro and in vivo; induces cell transformation in hamster embryo cells | Mutagenic in Salmonella; clastogenic in mammalian cells; inconsistent evidence for DNA damage in mammalian cells in vitro and in vivo; induces cell transformation in hamster embryo cells
ADME evaluation (see Step 4) | ND; metabolic pathways expected to be similar to other TDA isomers based on metabolite prediction data | Common metabolic pathways with other TDA isomers (acetylation of the amino groups, ring hydroxylation, and potential oxidation of methyl groups) | Common metabolic pathways with other TDA isomers (acetylation of the amino groups, ring hydroxylation, and potential oxidation of methyl groups) | Common metabolic pathways with other TDA isomers (acetylation of the amino groups, ring hydroxylation, and potential oxidation of methyl groups)
Cancer data and MOA (see Step 5) | ND | Liver tumors in rats and mice, subcutaneous fibromas in male rats, mammary tumors in rats, lymphoma in female mice; MOA not established | No significant evidence of carcinogenicity (but doses may have been too low); MOA not established | Testicular tumors in rats, lung tumors in mice; MOA not established
Common SAs and SAR predictions (see Step 6) | ALERTS; Aromatic amine; Primary aromatic amine, hydroxyl amine, and its derived esters; Primary aromatic amine, hydroxyl amine, and its derived esters or amine-generating group; Substituted anilines; Single ring-substituted primary aromatic amines; SAR PREDICTIONS:; Concerns for mutagenicity and carcinogenicity in most models; no concern for nongenotoxic carcinogenicity in Toxtree | ALERTS; Aromatic amine; Primary aromatic amine, hydroxyl amine, and its derived esters; Primary aromatic amine, hydroxyl amine, and its derived esters or amine-generating group; Substituted anilines; Single ring-substituted primary aromatic amines; SAR PREDICTIONS:; Concerns for mutagenicity and carcinogenicity in most models; no concern for nongenotoxic carcinogenicity in Toxtree | ALERTS; Aromatic amine; Primary aromatic amine, hydroxyl amine, and its derived esters; Primary aromatic amine, hydroxyl amine, and its derived esters or amine-generating group; Substituted anilines; Single ring-substituted primary aromatic amines; SAR PREDICTIONS:; Concerns for mutagenicity and carcinogenicity in most models; no concern for carcinogenicity in two of three VEGA models and no concern for nongenotoxic carcinogenicity in Toxtree | ALERTS; Aromatic amine; Primary aromatic amine, hydroxyl amine, and its derived esters; Primary aromatic amine, hydroxyl amine, and its derived esters or amine-generating group; Substituted anilines; Single ring-substituted primary aromatic amines; SAR PREDICTIONS:; Concerns for mutagenicity and carcinogenicity in most models; no concern for carcinogenicity in one of three VEGA models; not likely to be a carcinogen based on QSAR in Toxtree; and no concern for nongenotoxic carcinogenicity in Toxtree

ADME = absorption, distribution, metabolism, and excretion; CA = chromosomal aberration; DNA = deoxyribonucleic acid; m- = meta; MOA = mode of action; ND = no data; o- = ortho; p- = para; QSAR = quantitative structure-activity relationship; SA = structural alert; SAR = structure-activity relationship; TDA = toluenediamine; VEGA = Virtual models for property Evaluation of chemicals within a Global Architecture.

## STEP 8 QUALITATIVE LEVEL OF CONCERN FOR 2,3-TDA POTENTIAL CARCINOGENICITY

A concern for potential carcinogenicity for 2,3-TDA is identified based on the multiple lines of evidence, including similarities in structural features, in silico metabolism profiles, SAs, and SAR predictions, and experimental data for carcinogenicity and/or genotoxicity for the target and analogues (see Table C-7 for additional details). Because of the lack of information supporting carcinogenic portal-of-entry effects, the qualitative level of concern for this chemical is considered to be applicable to all routes of exposure.

Table C-7 Qualitative Level of Concern for Carcinogenicity of 2,3-Toluenediamine (CASRN 2687-25-4)

Level of Concern | Designation | Comments
Concern for potential carcinogenicity | Selected | 2,4-, 2,5-, and 2,6-TDA were identified as structural analogues of 2,3-TDA for evaluating carcinogenic potential. These compounds are TDA isomers that share a basic chemical structure (benzene ring, two amino groups, and a methyl group), differing only in the position of the amino functional groups. The analogues exhibit commonalities in toxicokinetic properties, including common metabolic pathways, which are expected to be similar for 2,3-TDA based on metabolite predictions. Two of three analogues have carcinogenic potential based on tumors observed in rodent studies (2,4- and 2,5-TDA); the third analogue (2,6-TDA) has not been adequately assessed for carcinogenicity. Although the carcinogenic MOA for 2,3- 2,4-, 2,5-, and 2,6-TDA is not known, all compounds show some evidence of mutagenicity in bacterial systems with metabolic activation, and the analogues show genotoxic potential in mammalian test models. Furthermore, the target compound and analogues have identical SAs (e.g., aromatic amine) and similar SAR predictions showing concern for carcinogenicity/genotoxicity.
Inadequate information for assigning qualitative level of concern | Not selected | NA

MOA = mode of action; NA = not applicable; SA = structural alert; SAR = structure-activity relationship; TDA = toluenediamine.