# APPENDIX A SCREENING NONCANCER PROVISIONAL VALUES

Due to the lack of evidence described in the main Provisional Peer-Reviewed Toxicity Value (PPRTV) document, it is inappropriate to derive provisional toxicity values for 2,3-toluenediamine (2,3-TDA). However, some information is available for this chemical, which although insufficient to support derivation of a provisional toxicity value under current guidelines, may be of limited use to risk assessors. In such cases, the Center for Public Health and Environmental Assessment (CPHEA) summarizes available information in an appendix and develops a “screening value.” Appendices receive the same level of internal and external scientific peer review as the provisional reference values to ensure their appropriateness within the limitations detailed in the document. Users of screening toxicity values in an appendix to a PPRTV assessment should understand that there could be more uncertainty associated with deriving an appendix screening toxicity value than for a value presented in the body of the assessment. Questions or concerns about the appropriate use of screening values should be directed to the CPHEA.

## APPLICATION OF AN ALTERNATIVE ANALOGUE APPROACH

The analogue read-across approach allows for the use of data from related compounds to calculate screening values when data for the compound of interest are limited or unavailable. Details regarding searches and methods for analogue analysis are presented in Wang et al.(2012). Three types of potential analogues (structural, metabolic, and toxicity-like) are identified to facilitate the final analogue chemical selection. The analogue approach may or may not be route specific or applicable to multiple routes of exposure. All information was considered together as part of the final weight-of-evidence (WOE) approach to select the most suitable analogue both toxicologically and chemically.

### Structural Analogues

An initial analogue search focused on the identification of structurally similar chemicals with toxicity values from the Integrated Risk Information System (IRIS), PPRTV, Agency for Toxic Substances and Disease Registry (ATSDR), or California Environmental Protection Agency (CalEPA) databases to take advantage of the well-characterized chemical-class information. This was accomplished by searching structural similarity software tools, namely the National Library of Medicine’s (NLM) ChemIDplus database (NLM, 2019) and Organisation for Economic Co-operation and Development (OECD) quantitative structure-activity relationship (QSAR) Toolbox (OECD, 2019). These software tools employ slightly different quantitative methods to make similarity comparisons between chemical structures based on fingerprints, ChemIDplus uses a modified Tanimoto index and the OECD Toolbox uses the Dice index. Two TDA isomers that have oral noncancer toxicity values were identified as potential structural analogues of 2,3-TDA: 2,6-TDA (U.S. EPA, 2005b) and 2,5-TDA (U.S. EPA, 2013) (see Table A-1). In addition, 3,4-TDA (a compound being evaluated in a separate PPRTV assessment) and 2,4-TDA were included in the read-across analysis to provide information on the influence of the position of the amino groups (ortho [o-], meta [m-], or para [p-]) on toxicity (see Table A-1). Previous structure-activity relationship (SAR) analyses have suggested increased chemical reactivity and toxicity for o- and p- versus m-substituted aromatic amines (Bajot et al., 2010). The target and 2,3-TDA are o- isomers, 2,5-TDA is a p- isomer and 2,4- and 2,6-TDAs are m- isomers.

Table A-1 summarizes the physicochemical properties and similarity scores for all analogues. 2,3-TDA and the identified analogues are aromatic amines that share a common basic structure, which consists of a benzene ring, two amino groups, and a methyl group, differing only in the position of the amino functional groups. These compounds are major components of commercial-grade TDA mixtures (WHO, 1987) and have physicochemical properties that are of the same relative order of magnitude; therefore, differences in the absorption and distribution between the analogues and the target are not expected to be significant or result in a preference in the selection of one analogue over another. These compounds are all weak bases and are expected to be substantially ionized at physiological pH values. Furthermore, their water solubility and octanol-water partition coefficient (log K_ow_) values are consistent with a high degree of hydrophilicity (see Table A-1). Additionally, all of these diamines have low volatility and are not expected to be eliminated in exhaled breath.

Structural alert (SA) predictions for relevant toxicity endpoints were generated for the TDA isomers using the OECD QSAR Toolbox [OECD (2019); see Table A-2]. These included the repeated-dose profiler based on the Hazard Evaluation Support System (HESS) database and the developmental and reproductive toxicity (DART) scheme adapted from the Wu et al. (2013) framework for identifying chemicals with structural features associated with potential reproductive/developmental (R/D) toxicants. The model predictions suggest concern for hepatotoxicity, hemolytic anemia with methemoglobinemia, and for R/D toxicity for 2,3-TDA and all analogues. The predictions are based on SAs for aniline and toluene/small alkyl toluene derivatives, respectively. The HESS model also showed concern for renal toxicity for 2,3-, 3,4-, and 2,6-TDA based on SA for toluene.

In summary, the candidate analogues are considered suitable analogues for 2,3-TDA based on their similarities in structural and physicochemical properties and SA predictions.

Table A-1 Physicochemical Properties of 2,3-Toluenediamine (CASRN 2687-25-4) and Candidate Analogues^a^

Property | 2,3-Toluenediamine | 3,4-Toluenediamine | 2,4-Toluenediamine | 2,5-Toluenediamine | 2,6-Toluenediamine
Role | Target | Analogue | Analogue | Analogue | Analogue
Structure | structure diagram | structure diagram | structure diagram | structure diagram | structure diagram
CASRN | 2687-25-4 | 496-72-0 | 95-80-7 | 95-70-5 | 823-40-5
DTXSID | 9024930 | 4027494 | 4020402 | 6029123 | 4027319
Molecular weight | 122 | 122 | 122 | 122 | 122
ChemIDplus similarity score (%)^b^ | 100 | 70 | 54 | 61 | 67
OECD toolbox similarity score (%)^c^ | 100 | 67 | 78 | 78 | 78
Melting point (°C) | 60.1 | 88.8 | 98.2 | 64.0 | 105
Boiling point (°C) | 254 | 243 | 286 | 274 | 260
Vapor pressure (mm Hg) | 5.53 × 10^−4^ | 6.29 × 10^−4^ | 1.7 × 10^−4^ | 2.25 × 10^−3^ (predicted) | 2.46 × 10^−3^
Henry’s law constant (atm-m^3^/mole at 25°C) | 5.59 × 10^−8^ (predicted) | 5.59 × 10^−8^ (predicted) | 5.60 × 10^−8^ (predicted) | 5.73 × 10^−8^ (predicted) | 5.61 × 10^−8^ (predicted)
Water solubility (mol/L) | 2.36 (predicted) | 2.39 (predicted) | 2.57 (predicted) | 2.73 (predicted) | 2.52 (predicted)
Octanol-water partition coefficient (log K_ow_) | 0.549 (predicted) | 0.66 | 0.14 | 0.11 (predicted) | 0.21 (predicted)
Acid dissociation constant (pKa) (unitless) | 4.91 (predicted)^d^ | 5.00 | 5.58 (predicted)^e^ | 6.52 (predicted)^e^ | 5.28 (predicted)^e^

a Data were extracted from the U.S. EPA CompTox Chemicals Dashboard (https://comptox.epa.gov/dashboard. Accessed on April 20, 2021). All values are experimental averages unless otherwise specified.

b ChemIDplus advanced similarity scores (NLM, 2019).

c OECD QSAR Toolbox, similarity scores (OECD, 2019).

d HSDB (2013b).

e ChemAxon (2017).

OECD = Organisation for Economic Co-operation and Development; QSAR = quantitative structure-activity relationship.

Table A-2 Comparison of SAs for Relevant Endpoints for 2,3-Toluenediamine (CASRN 2687-25-4) and Analogues from the OECD QSAR Toolbox^a^

SA | 2,3-Toluenediamine CASRN 2687-25-4 | 3,4-Toluenediamine CASRN 496-72-0 | 2,4-Toluenediamine CASRN 95-80-7 | 2,5-Toluenediamine CASRN 95-70-5 | 2,6-Toluenediamine CASRN 823-40-5
Repeated-dose toxicity (HESS) | - Hepatotoxicity (anilines); - Hemolytic anemia with methemoglobinemia (anilines); - Renal toxicity (toluene) | - Hepatotoxicity (anilines); - Hemolytic anemia with methemoglobinemia (anilines); - Renal toxicity (toluene) | - Hepatotoxicity (anilines); - Hemolytic anemia with methemoglobinemia (anilines) | - Hepatotoxicity (anilines); - Hemolytic anemia with methemoglobinemia (anilines) | - Hepatotoxicity (anilines); - Hemolytic anemia with methemoglobinemia (anilines); - Renal toxicity (toluene)
DART scheme | - Known precedent reproductive and developmental toxic potential (toluene and small alkyl toluene derivatives) | - Known precedent reproductive and developmental toxic potential (toluene and small alkyl toluene derivatives) | - Known precedent reproductive and developmental toxic potential (toluene and small alkyl toluene derivatives) | - Known precedent reproductive and developmental toxic potential (toluene and small alkyl toluene derivatives) | - Known precedent reproductive and developmental toxic potential (toluene and small alkyl toluene derivatives)

a OECD QSAR Toolbox (OECD, 2019).

DART = developmental and reproductive toxicity; HESS = Hazard Evaluation Support System; OECD = Organisation for Economic Co-operation and Development; QSAR = quantitative structure-activity relationship; SA = structural alert.

### Metabolic Analogues

Table A-3 summarizes available toxicokinetic data for 2,3-TDA and the structurally similar compounds identified as candidate analogues.

No toxicokinetic data has been identified for 2,3-TDA. Available information on the 2,4-, 2,5-, and 2,6-TDA analogues suggest that these compounds are rapidly and extensively absorbed following oral exposure and are rapidly eliminated in the urine, which is a predominant route of excretion (see Table A-3). Major metabolic steps for the TDA analogues are acetylation of amino groups and ring hydroxylation, with some evidence for oxidation of the methyl groups in rats and mice exposed via intraperitoneal (i.p.) administration (see Table A-3).

In the absence of in vivo toxicokinetic data on 2,3-TDA, a selection of available software tools, specifically the in vivo and in vitro rat metabolic simulators available within the Tissue Metabolism Simulator (TIMES) program (Dimitrov et al., 2005; Mekenyan et al., 2004) and Meteor Nexus (Marchant et al., 2008) were used to predict metabolites for the target compound and analogues. Predicted metabolites for the TDA isomers are summarized in Tables D-1 and additional information on the in silico analysis can be found in Appendix D. The analysis reveals some overlap in terms of metabolites for the individual TDA compounds across the different tools and when comparing predictions with experimental data from in vivo rodent studies (captured in Table A-3), which increases confidence in the in silico results. Furthermore, the corresponding metabolic pathway transformations were extracted from Meteor Nexus to allow for similarity comparisons across the TDAs. This level of information was not available from other tools (i.e., TIMES). Table A-4 shows a consistent pattern of pathway transformations among the TDA compounds, and Figure A-1 confirms a high degree of similarity between 2,3-TDA and the candidate analogues with regards to the Meteor Nexus pathway predictions. There is also concordance between the in silico results (see Table A-4) and the major pathways expected for this group of compounds (N-acetylation, ring hydroxylation, and oxidation of methyl groups). Importantly, no outstanding differences in the predicted metabolic profiles between the target and analogues are noted. The metabolic tree for 2,4-TDA is displayed in Figure D-1 of Appendix D to illustrate the relationship of the predicted metabolites for this specific analogue that correspond to the pathway transformations shared among the TDAs.

In summary, in vivo data demonstrate toxicokinetic commonalities among the analogues, particularly with respect to metabolism pathways, and according to in silico predictions, a similar metabolism pattern is expected for 2,3-TDA. Therefore, the candidate analogues are considered suitable analogues for 2,3-TDA based on their toxicokinetic properties.

Table A-3 Comparison of Available ADME Data for 2,3-Toluenediamine (CASRN 2687-25-4) and Candidate Analogues

2,3-Toluenediamine CASRN 2687-25-4 | 3,4-Toluenediamine CASRN 496-72-0 | 2,4-Toluenediamine CASRN 95-80-7 | 2,5-Toluenediamine CASRN 95-70-5 | 2,6-Toluenediamine CASRN 823-40-5
structure diagram | structure diagram | structure diagram | structure diagram | structure diagram
Target | Analogue | Analogue | Analogue | Analogue
DTXSID 4027494 | DTXSID 9024930 | DTXSID 4020402 | DTXSID 6029123 | DTXSID 4027319
Absorption
ND | ND | [underlined: Rats exposed orally (single dose of 3 or 60 mg/kg):]; - 70% of administered dose based on recovered radioactivity in the urine and tissue/carcass over 48 h; [underlined: Rats exposed via i.p. injection (single 77-mg/kg dose):]; - Rapid absorption; levels peaked in blood and plasma 1 h after dosing | [underlined: Rats exposed orally (single dose of 2.5 to 25 mg/kg):]; - Blood radioactivity peaked at 1 h after dosing (as sulfate); - Time to C_max_ in blood 0.5–1 h after dosing (as sulfate) | [underlined: Rats exposed orally (single dose of 10 mg/animal; approximately 57 to 67 mg/kg based on a reported body weights of 150–175 g):]; - Rapidly and extensively absorbed
Distribution
ND | ND | [underlined: Rats exposed orally (single dose of 3 or 60 mg/kg):]; - 2–5% in tissue and carcass (after 48 h); [underlined: Rats and mice exposed via i.p. injection (single 77 mg/kg dose):]; - Liver and kidney > blood > muscle; high levels also in GI tract, spleen, heart, testes, lymph nodes, eyes, and lungs; - Mouse tissues showed lower level of radioactivity than rat tissues | ND | [underlined: Rats exposed orally (single dose of 10 mg/animal; approximately 57 to 67 mg/kg based on a reported body weights of 150–175 g):]; Wide distribution following single dose (% of administered dose); - 3.6% large intestine; - 1% muscle; - 0.6% liver; - 0.5% skin; - 0.2% blood; - 0.1% small intestine; - >0.1% for perirenal fat, stomach contents, brain, spleen, testis, heart, and lungs
Metabolites
ND | ND | [underlined: Rats exposed orally (single 50-mg/kg dose):]; Urinary over 48 h (% dose excreted); - 3-Hydroxy-4-acetylamino-2-aminotoluene (18%); - 5-Hydroxy-4-acetylamino-2-aminotoluene (14%); - 5-Hydroxy-2,4-diaminotoluene (12%),3-hydroxy-2,4-diaminotoluene (8%) and 6-hydroxy-2,4-diaminotoluene (5%); - Other (unidentified) conjugates (16–34% of all acid-labile conjugates); [underlined: Rats exposed via i.p. injection (single 77-mg/kg dose):]; Urinary over 24 h (% dose); - Free metabolites (20.9%), including 4-acetylamino-2-aminotoluene, (5.7%), 4-acetyl amino-2-amino benzoic acid (2.7%), and 2,4-diacetylamino toluene (2.6%); - Glucuronide conjugates (7.5%); - Sulfate conjugates (10.1%); - Water soluble (30.9%); [underlined: Mice exposed via i.p. injection (single 77-mg/kg dose):]; Urinary over 24 h (% dose); - Free metabolites (20.2%), including 4-acetylamino-2-aminobenzoic acid (5.4%), 4-acetylamino-2-aminotoluene (2.1%), and 2,4-diacetyl aminobenzoic acid (1.1%); - Glucuronide conjugates (17.4%); - Sulfate conjugates (9.6%); - Water soluble (35.3%) | [underlined: Rats exposed orally to sulfate salt (single dose of 2.5 or 25 mg/kg):]; Urinary over 96 h; - N,N′-Diacetyl-toluene-2,5-diamine; - Two unidentified mono-N-acetylated metabolites; [underlined: Rats exposed by i.v. injection (single 2.5-mg/kg dose):]; Urine and feces over 96 h; - 2,5-Diacetylamino toluene was a major metabolite | [underlined: Rats exposed orally (single dose of 10 mg/animal; approximately 57 to 67 mg/kg based on a reported body weights of 150–175 g):]; Urinary over 24 h; - 3-Hydroxy-2,6-toluenediamine; - 5-Hydroxy-2-acetylamino-6-aminotoluene; - 2-Acetylamino-6-aminotoluene; - 2,6-Diacetylamino toluene; - No parent compound detected
Excretory pattern after oral exposure (unless otherwise indicated)
ND | ND | [underlined: Rats exposed orally (single dose of 3 or 60 mg/kg):]; Urine (% dose): >60% (within 48 h); Feces (% dose): 23–31 (within 48 h) | [underlined: Rats exposed orally (single dose of 2.5 or 25 mg/kg):]; Urine (% dose): >60 (within 98 h); Feces (% dose): 22–31 (within 98 h) | [underlined: Rats exposed orally (single dose of 10 mg/animal; approximately 57 to 67 mg/kg based on a reported body weights of 150–175 g):]; Urine (% dose): 85 (within 24 h); Feces (% dose): 10 (within 72 h); Exhaled air (% dose): 0
References
NA | NA | Timchalk et al. (1994); Grantham et al.(1979); Waring and Pheasant (1975) | Wenker (2005c), Wenker (2005c), Wenker (2005a), and Charles River Laboratories (2010) as cited in SCCS (2012), pages 50–52 and 56–57 | Cunningham et al. (1989)

ADME = absorption, distribution, metabolism, excretion; C_max_ = maximum concentration; GI = gastrointestinal; i.p. = intraperitoneal; i.v. = intravenous; NA = not applicable; ND = no data.

Table A-4 Comparison of Metabolic Pathway Transformations for 2,3-Toluenediamine (CASRN 2687-25-4) and Candidate Analogues from Meteor Nexus^a,^ ^b^

Pathway | 2,3-TDA | 3,4-TDA | 2,4-TDA | 2,5-TDA | 2,6-TDA
5-Hydroxylation of 1,2,4-trisubstituted benzenes | 0 | 1 | 1 | 1 | 0
Hydroxylamines from primary aromatic amines | 1 | 1 | 1 | 1 | 1
Hydroxylation of methyl carbon next to an aromatic ring | 1 | 1 | 1 | 1 | 1
N-Acetylation of primary aromatic amines | 1 | 1 | 1 | 1 | 1
O-Sulfonation of aromatic alcohols | 0 | 0 | 1 | 0 | 0
O-Sulfonation of N-hydroxy compounds | 1 | 1 | 1 | 1 | 1
Oxidation of primary alcohols | 1 | 1 | 1 | 1 | 1

a Meteor Nexus (Dimitrov et al., 2005; Mekenyan et al., 2004).

b 1/0 denotes whether pathway transformation was identified/not identified.

TDA = toluenediamine.

Figure A-1 Metabolic Pathway Similarities for 2,3-Toluenediamine (CASRN 2687-25-4) and Candidate Analogues

Heatmap displays Jaccard pairwise similarities rounded to two decimal places for the TDA compounds, comparing metabolic pathway transformations from Meteor Nexus (Dimitrov et al., 2005; Mekenyan et al., 2004).

This is the beginning of the long description for Figure A dash 1. Figure A dash 1 is titled Metabolic Pathway Similarities for 2 3 Toluenediamine, C A S Registry Number 2 6 8 7 dash 2 5 dash 4, and Candidate Analogues. The figure is a heatmap block graph with each block showing the Jaccard similarity scores for 2 3 Toluenediamine and candidate analogues. This is the end of the long description for Figure A dash 1.

### Toxicity-Like Analogues

Table A-5 summarizes available subchronic and chronic oral toxicity data for 2,3-TDA and the compounds identified as candidate analogues. None of the analogues had subchronic or chronic inhalation toxicity values from U.S. EPA, ATSDR, or CalEPA.

No repeated-dose oral toxicity data are available for the 2,3-TDA isomer. Oral toxicity values are available for 2,5- and 2,6-TDA. Hepatic effects were the basis for the subchronic and chronic provisional reference doses (p-RfDs) for 2,5-TDA sulfate using a point of departure (POD) of 2.5 mg/kg-day (1.4 mg/kg-day for the free base estimated for this assessment) (U.S. EPA, 2013). Thyroid and body-weight effects were the basis for the subchronic p-RfD for 2,6-TDA using a POD of 62 mg/kg-day (U.S. EPA, 2005b). The chronic p-RfD for 2,6-TDA was derived based on a POD of 25 mg/kg-day for no adverse effects (U.S. EPA, 2005b). Although thyroid toxicity was only noted following 2,6-TDA exposure, liver effects (ranging from changes in serum biomarkers and liver weight to gross and histopathological lesions) were reported after exposure to 2,4- (≥6 mg/kg-day), 2,5- (≥3 mg/kg-day), and 2,6-TDA (692 mg/kg-day) (U.S. EPA, 2013, 2005b; Criteria Group for Occupational Standards, 2001; WHO, 1987).

R/D toxicity was commonly seen with exposure to TDA compounds, but these endpoints were generally less sensitive than the systemic effects described above. Impaired male fertility and sperm damage were reported in male rats orally exposed to 2,4-TDA at 15 mg/kg-day (Criteria Group for Occupational Standards, 2001). Developmental effects were observed in laboratory animals orally exposed to 2,6- (≥100 mg/kg-day) or 2,5-TDA (≥44 mg/kg-day) during gestation, primarily at doses associated with potential maternal toxicity (U.S. EPA, 2013; WHO, 1987). Data on the o-TDA mixture (40:60 or 45:50 mixture of 2,3- and 3,4-TDA) showed possible evidence of R/D effects in rats and rabbits exposed to ≥100 mg/kg-day via gavage, including alterations in sperm measures (decreased spermatid number) and/or fetal viability and growth (decreased implantation sites, litter size, pup viability, and fetal weight, as well as increased post implantation loss, resorptions, and skeletal variations) often accompanied by reductions in maternal body-weight gain (BASF, 2010; Becci et al., 1983). These findings suggest that the reproductive system and developing embryo/fetus may be toxicity targets of 2,3- and 3,4-TDA.

Acute lethality studies via different exposure routes were available for o- (2,3- and 3,4-) and m- (2,4- and 2,6-) TDA mixtures and individual TDA isomers (see Table A-6). The oral median lethal dose (LD_50_) value for 2,5-TDA (102 mg/kg) in rats was lower than the LD_50_ values for o- (660 and 810 mg/kg) and m-TDA (270 and 300 mg/kg) mixtures. In mice, the i.p. LD_50_ values for 2,3-TDA (286 mg/kg) and a m-TDA mixture (240 mg/kg) were similar. Likewise, the rabbit dermal LD_50_ value for a o-TDA mixture (1,120 mg/kg) was similar to the rat dermal LD_50_ value for a m-TDA mixture (1,200 mg/kg). Central nervous system depression and methemoglobinemia have been associated with high-dose, acute TDA toxicity in animals (WHO, 1987).

SAR evaluations have suggested increased chemical reactivity for o- and p-substituted aromatic amines such as 2,3-, 3,4-, and 2,5-TDA based on their oxidation potential into reactive quinones that can interact with glutathione to produce reactive oxygen species (ROS) (Bajot et al., 2010). In contrast, m-substituted aromatic amines such as 2,4- and 2,6-TDA are less likely to form quinones and are therefore expected to have decreased chemical reactivity (Bajot et al., 2010). The o- and p- substituents were also associated with enhanced, acute aquatic toxicity compared to m- substituents (Bajot et al., 2010). No experimental data was found to evaluate potential differences in chemical reactivity for the TDA isomers. The available evidence in animals shows consistency with respect to toxicity targets (primarily liver and R/D effects) among this group of compounds, and although potency differences are apparent in some cases, there is no clear pattern with respect to the position of the amino groups.

In summary, limited toxicity data for 2,3-TDA from mixture studies reveals similarities in acute toxicity potency and R/D outcomes between the target and analogues. As such, the candidate analogues are considered suitable analogues for 2,3-TDA on the basis of toxicity similarity comparisons.

Table A-5 Comparison of Available Oral Toxicity Data and Health Reference Values for 2,3-Toluenediamine (CASRN 2687-25-4) and Candidate Analogues

Parameter | 2,3-Toluenediamine CASRN 2687-25-4 | 3,4-Toluenediamine CASRN 2687-25-4 | 2,4-Toluenediamine CASRN 95-80-7 | 2,5-Toluenediamine CASRN 95-70-5 | 2,6-Toluenediamine CASRN 823-40-5
Role | Target | Analogue | Analogue | Analogue | Analogue
DTXSID | 9024930 | 4027494 | 4020402 | 6029123 | 4027319
Structure | structure diagram | structure diagram | structure diagram | structure diagram | structure diagram
Repeated-dose toxicity―subchronic studies
Effects | NA | In a 5-d study in rats (n = 13), exposure to 3,4-TDA (97% purity) at a dose of 1,000 mg/kg-d for 5 d resulted in 7/13 deaths; 6 animals had grossly observed perforated duodenal ulcers. | In a 14-d study in female mice (n = 6–8/group) exposed to 25, 50, or 100 mg/kg-d of 2,4-TDA (98.4% purity), increased B cells in spleens, and lower spleen weights were observed at ≥25 mg/kg-d, and changes in hepatic enzymes in serum and elevated liver weights were observed at 100 mg/kg-d. Unclear whether organ-weight changes were absolute and/or relative.; A 7-wk study exposed rats (n = 5/sex/group) to 0, 250, 500, 1,000, 2,000, or 3,000 ppm and mice (n = 5/sex/group) to 0, 100, 200, 300, 500, 700, or 1,000 ppm of 2,4-TDA (>99.9% purity) via the diet. Decreased body weights, elevated hematopoiesis, and histopathological liver changes were observed in rats at 1,000 ppm (~75 mg/kg-d). The same diet resulted only in decreased body weights in mice. | Groups of 15 male and female rats were gavaged with doses of 0, 2.5, 5, 10, or 20 mg/kg-d 2,5-TDA sulfate (99.7% purity) for 13 wk. Increased serum AST in females at 5 mg/kg-d (3 mg/kg-d as free base), increased urine with decrease in specific gravity at ≥10 mg/kg-d (6 mg/kg-d as free base), and abnormally shaped pituitary glands at 20 mg/kg-d (11 mg/kg-d as free base) were observed (refer to “Noncancer Oral Toxicity Values” below for additional details).; In an accompanying range-finding study in rats (n = 10/sex/group) gavaged with 0, 7.5, 15, 30, or 60 mg/kg-d of 2,5-TDA sulfate, variations in serum CPK, AST, and LDH and increased absolute and relative liver weight were seen at ≥30 mg/kg-d (20 mg/kg-d as free base). | A 91-d dietary exposure study in rats (n = 10/sex/group) dosed with 0, 100, 300, 1,000, 3,000, or 10,000 ppm of 2,6-TDA dihydrochloride (>99% purity). Thyroid hyperplasia in males and decreased body weight (both sexes) were observed at 192 mg/kg-d (as free base); thyroid hyperplasia was observed in females at 767 mg/kg-d (highest dose as free base).; Other effects observed at the high dose (692 mg/kg-d in males and 767 mg/kg-d in females as free base) included thyroid enlargement; darkening of spleen, lymph nodes, liver, kidney, adrenals, and nasal turbinates; histopathological lesions in the kidney (nephrosis) and bone marrow (hyperplasia); and death.; In the companion mouse study, reduced body weight was also observed; however, exposure levels were unclear. No pathological changes were noted.
Sources | NA | Selye (1973) | Bums et al. (1994) and NCI (1979) as cited in Criteria Group for Occupational Standards (2001) | Hill (1997, 1994) as cited in U.S. EPA (2013) | NTP (1980) as cited in U.S.EPA (2005b)
Repeated-dose toxicity―chronic studies
Effects | NA | NA | A 2-yr NTP bioassay exposed groups of 20–50 rats (time-weighted average doses of 0, 79, or 171–176 ppm) and mice (0, 100, or 200 doses) to 2,4-TDA (>99.9% purity). Reduced body weight and histopathological changes in the liver (lesions ranged from cellular alterations to severe degenerative changes in rats and hyperplasia in mice) were observed in exposed animals [at doses ~ ≥6 mg/kg-d in rats and ≥17 mg/kg-d in mice estimated for this analysis using U.S. EPA (1988) default values for BW and food intake]. Decreased survival, kidney histopathology (chronic renal disease) and secondary hyperthyroidism associated with renal disease were also reported in rats at same doses. | In a 78-wk cancer bioassay, rats and mice were exposed to 2,5-TDA toluene sulfate (>99% purity) at time-weighted average concentrations of 0.06 or 0.2% and 0.06 or 0.1% in the diet, respectively (n = 50/species/sex/group); no exposure-related changes in clinical signs, survival, growth, or non-neoplastic histology were observed up to the highest doses tested (~95 mg/kg-d as free base). | In a 103-wk study in rats (n = 50/sex/group) exposed to 0, 250, or 500 ppm of 2,6-TDA dihydrochloride (>99%) in the diet, no adverse effects were reported up to 500 ppm (25 and 30 mg/kg-d in males and females, respectively as free base).; In the companion mouse study (n = 50/sex/group) with exposure to 0, 50, or 100 ppm, no adverse effects were observed at doses up to 100 ppm 2,6-TDA dihydrochloride (10 mg/kg-d for both males and females as free base).
Source | NA | NA | NCI (1979) as cited in Criteria Group for Occupational Standards (2001) and WHO (1987) | NTP (1978) as cited in U.S. EPA (2013) | NTP (1980) as cited inU.S. EPA (2005b)
Reproductive/developmental studies
Effects | An R/D screen in rats (n = 10/sex/group) exposed to a 45:50 mixture of 2,3- and 3,4-TDA (0, 10, 50, or 250 mg/kg-d doses) reported clinical signs, decreased food consumption and body weight, decreased number of spermatids/g testis, decreased number of implantation sites, increased post implantation loss, decreased litter size, and decreased pup viability at 250 mg/kg-d.; Gestational exposure studies in pregnant rats (n = 22/group) and rabbits (n = 15/group) with exposure to a 40:60 mixture of 2,3- and 3,4-TDA (0, 10, 30, 100, or 300 mg/kg-d and 0, 3, 10, 30, or 100 mg/kg-d for rats and rabbits, respectively) reported increased incidences of skeletal variations at ≥100 mg/kg-d and reduced maternal body-weight gain and reduced fetal weight at 300 mg/kg-d in rats. Reduced maternal body-weight gain, reduced fetal weight, increased number of resorption sites, and decreased numbers of live fetuses/litter were reported at 100 mg/kg-d in rabbits.; Refer to the “Reproductive/Developmental Studies of TDA Mixtures” section in the main document for additional study details. | | Three studies evaluated male reproductive effects in rats (n = 8–10/group) after a 10-wk exposure in the diet containing 0, 0.01, or 0.03% 2,4-TDA (98% purity); they reported decreased fertility and inhibition of sperm production, altered serum reproductive hormones, and histological changes in the reproductive organs at the highest exposure level (~15 mg/kg-d). | Gestational exposure studies in animals (n = 16-30/group) gavaged with 2,5-TDA sulfate (purity unspecified) reported decreased maternal body weight at ≥50 mg/kg-d (28 mg/kg-d as free base) and increased resorptions at 80 mg/kg-d in rats (44 mg/kg-d as free base). Increased maternal and neonatal mortality were observed at 160 mg/kg-d in mice (88 mg/kg-d as free base), and no adverse effects were observed in rabbits at doses up to 50 mg/kg-d (28 mg/kg-d as free base). Exposure doses were 0, 10, 50, or 80 mg/kg-d in rats (GDs 6–15), 0, 10, 35, or 50 mg/kg-d in rabbits (GDs 6–18) and 160 mg/kg-d in mice (GDs 8–12).; A 2-generation reproductive toxicity study in rats (n = 24/sex/group) exposed to 0, 5, 15, or 45 mg/kg-d 2,5-TDA sulfate (98.2% purity) reported no effects in clinical signs, body-weight gain, food consumption, male and female fertility, or fetal growth and survival up to the highest dose (~25 mg/kg-d as free base). | A gestational exposure study (GDs 6–15) in rats (number of animals and 2,6-TDA purity not specified) gavaged with 0, 10, 30, 100, or 300 mg/kg-d showed increased incidence of hemorrhagic abdomens at ≥30 mg/kg-d and skeletal variations at ≥100 mg/kg-d following exposure to 2,6-TDA, with reduced maternal weight gain at 300 mg/kg-d. An accompanying study in rabbits (GDs 6–18) exposed to 0, 3, 10, 30, or 100 mg/kg-d showed reduced maternal weight, increased resorptions, decreased fetal weight, and decreased neonatal survival following gavage exposure to 2,6-TDA at 100 mg/kg-d.
Source | BASF (2010); Becci et al. (1983) | | Varma et al. (1988); Thysen et al. (1985a) and (1985b) as cited in Criteria Group for Occupational Standards (2001) | Bornatowicz (1986), Osterburg (1982), Seidenberg et al. (1986), and Kavlock et al. (1987) as cited in U.S. EPA (2013) | Knickerbocker et al. (1980) as cited in WHO (1987)
Health reference values―subchronic
POD (mg/kg-d) | NA | NA | NA | 2.5 (as 2,5-TDA sulfate);; 1.4 (as free base estimated for this assessment) | 62 (as free base)
POD type | NA | NA | NA | NOAEL | NOAEL
UF_C_ | NA | NA | NA | 1,000 (UF_A_, UF_D_, UF_H_) | 1,000 (UF_A_, UF_D_, UF_H_)
p-RfD (mg/kg-d) | NA | NA | NA | 3 × 10^−3^ (as 2,5-TDA sulfate);; 2 × 10^−3^ (as free base)^a^; Note: screening value owing to use of secondary source | 6 × 10^−2^ (as free base)
Critical effects | NA | NA | NA | Increased serum AST in females. | Thyroid hyperplasia (males) and decreased body weight (both sexes).
Species | NA | NA | NA | Rat | Rat
Duration | NA | NA | NA | 13 wk (91 d) | 91 d
Route (method) | NA | NA | NA | Oral (gavage) | Oral (diet)
Sources | NA | NA | NA | Hill (1997) as cited in U.S. EPA (2013) | NTP (1980) as cited in U.S. EPA (2005b)
Health reference values―chronic
POD (mg/kg-d) | NA | NA | NA | 2.5 (as 2,5-TDA sulfate);; 1.4 (as free base estimated for this assessment) | 25 (as free base)
POD type | NA | NA | NA | NOAEL | NOAEL
UF_C_ | NA | NA | NA | 10,000 (UF_A_, UF_D_, UF_H_, UF_S_) | 1,000 (UF_A_, UF_D_, UF_H_)
p-RfD (mg/kg-d) | NA | NA | NA | 3 × 10^−4^ (as 2,5-TDA sulfate);; 2 × 10^−4^ (as free base)^a^; Note: screening value owing to the use of secondary source and UF_C_ >3,000. | 3 × 10^−2^ (as free base)
Critical effects | NA | NA | NA | Increased serum AST in females. | None
Species | NA | NA | NA | Rat | Rat
Duration | NA | NA | NA | 13 wk | 103 wk
Route (method) | NA | NA | NA | Oral (gavage) | Oral (diet)
Source | NA | NA | NA | Hill (1997) as cited in U.S. EPA (2013) | NTP (1980) as cited inU.S. EPA (2005b)

a The screening p-RfD values for 2,5-TDA as free base were calculated as follows: p-RfD for 2,5-TDA sulfate × (MW of 2,5-TDA as free base [122.17] ÷ MW of 2,5-TDA sulfate [220.25] = 0.55) (U.S. EPA, 2013).

AST = aspartate aminotransferase; BW = body weight; CPK = creatine phosphokinase; GD = gestation day; LDH = lactate dehydrogenase; MW = molecular weight; NA = not applicable; NOAEL = no-observed-adverse-effect level; NTP = National Toxicology Program; POD = point of departure; R/D = reproductive/developmental; p-RfD = provisional reference dose; TDA = toluenediamine; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

Table A-6 Comparison of Available Acute Lethality Data for 2,3-Toluenediamine (CASRN 2687-25-4) and Candidate Analogues

Parameter | 2,3-Toluenediamine CASRN 2687-25-4 | 3,4-Toluenediamine CASRN 496-72-0 | 2,5-Toluenediamine CASRN 95-70-5 | 2,4-Toluenediamine CASRN 95-80-7 | 2,6-Toluenediamine CASRN 823-40-5
Role | Target | Analogue | Analogue | Analogue | Analogue
DTXSID | 4027494 | 9024930 | 6029123 | 4020402 | 4027319
Structure | structure diagram | structure diagram | structure diagram | structure diagram | structure diagram
Rat oral LD_50_ (mg/kg) | 660 (mix of 2,3- and 3,4-TDA);; 810 (mix of 2,3- and 3,4-TDA) | | 102 | 270 and 300 (mix of 2,4- and 2,6-TDA)
Mouse oral LD_50_ (mg/kg) | NA | | NA | 350 (mix of 2,4- and 2,6-TDA)
Rat i.p. LD_50_ (mg/kg) | NA | | NA | 230 (mix of 2,4- and 2,6-TDA); 325 (2,4-TDA technical grade)
Mouse i.p. LD_50_ (mg/kg) | 286 | NA | NA | 240 (mix of 2,4- and 2,6-TDA); 90–480 (2,4-TDA technical grade)
Rabbit dermal LD_50_ (mg/kg) | 1,120 (mix of 2,3- and 3,4-TDA) | | NA | NA
Rat dermal LD_50_ (mg/kg) | NA | | NA | 1,200 (mix of 2,4- and 2,6-TDA)
Source | Air Products and Chemicals (1976); Carpenter et al. (1974); NLM (2019) | | NLM (2019) | Izmerov et al. (1982), Weisbrod and Stephan (1983), Grantham et al. (1979), and Weisburger et al. (1978) as cited in WHO (1987)

i.p. = intraperitoneal; LD_50_ = median lethal dose; NA = not available; TDA = toluenediamine.

### Weight-of-Evidence Approach

A WOE approach is used to evaluate information from candidate analogues as described by Wang et al. (2012). Commonalities in structural/physicochemical properties, toxicokinetics, metabolism, toxicity, or mode of action (MOA) between candidate analogues and chemical(s) of concern are identified. Emphasis is given to toxicological and/or toxicokinetic similarity over structural similarity. Analogues are excluded if they do not have commonality or demonstrate significantly different physicochemical properties and toxicokinetic profiles that set them apart from the pool of analogues and/or chemical(s) of concern. From the remaining analogues, the most appropriate analogue (most biologically or toxicologically relevant analogue chemical) with the highest structural similarity and/or most conservative toxicity value is selected.

#### Oral

2,5- and 2,6-TDA were identified as structural analogues of 2,3-TDA with available noncancer oral toxicity values. Two additional structural analogues were included in the read-across analysis, 3,4- and 2,4-TDA, to provide information on the potential influence of the position of the amino groups on toxicity. The analogues share a basic structure with the target compound (a benzene ring, two amino groups, and a methyl group, differing only in the position of the amino functional groups) and have similar physicochemical properties (i.e., water solubility, log K_ow_, volatility, etc.; see Table A-1) important for bioavailability. 2,3-TDA and its analogues also showed similar SA predictions for repeated-dose toxicity and R/D endpoints (see Table A-2). Evidence from oral and i.p. exposure studies in rodents suggests that the TDA analogues are predominantly metabolized via acetylation of amino groups, ring hydroxylation, and potential oxidation of methyl groups (see Table A-3). A comparative analysis of metabolite predictions across different software tools revealed a similar metabolic profile for the target compound and analogues and confirmed observations from in vivo studies (see “Metabolic Analogues” section above and Appendix D for more details). Repeated-dose toxicity studies showed commonalities in target tissues for the TDA analogues, most notably, liver and R/D toxicities (see Table A-5). No adequate toxicity data is available for the 2,3-TDA; however, studies evaluating TDA mixtures containing 2,3-TDA suggest similarities between the target and analogues with respect to acute toxicity potency and R/D outcomes (see Tables A-5 and A-6).

Similarities in structure, physicochemical properties, SA and metabolite predictions and limited toxicity data support the suitability of both 2,5- and 2,6-TDA (the two analogues with available toxicity values) as analogues of 2,3-TDA. 2,5-TDA is selected as the most appropriate analogue for deriving screening p-RfDs based on mechanistic considerations and health protectiveness. Although it is unclear how the position of the amino groups affects the repeated-dose toxicity of TDA compounds, the o- and p- isomers (2,3- and 2,5-TDA, respectively) are expected to have greater chemical reactivity (related to quinone formation) than the m- isomer (2,6-TDA). Furthermore, the POD values for 2,5-TDA (1.4 mg/kg-day for both the subchronic and chronic p-RfDs) are more than an order of magnitude lower than the POD values for 2,6-TDA (62 and 25 mg/kg-day for the subchronic and chronic p-RfDs, respectively).

#### Inhalation

None of the candidate analogues have repeated-dose inhalation toxicity values, precluding derivation of screening provisional reference concentrations (p-RfCs).

## NONCANCER ORAL TOXICITY VALUES

### Derivation of a Screening Subchronic Provisional Reference Dose

Based on the overall analogue approach presented in this PPRTV assessment, 2,5-TDA is selected as the analogue for 2,3-TDA for deriving a screening subchronic p-RfD. The study used for the U.S. EPA screening subchronic p-RfD for 2,5-TDA was a 13-week rat study [Hill (1997) as cited in SCCP (2007) and reported in U.S. EPA (2013)]. U.S. EPA (2013) described the study as follows:

Hill (1997, as cited in SCCP, 2007) administered toluene-2,5-diamine sulfate (99.7% pure) via gavage in deionized water to Sprague-Dawley rats (15/sex/dose) at 0, 2.5, 5, 10, or 20 mg/kg-day for 13 weeks. The original report for this study is not available; SCCP briefly described the study. Animals were observed daily for mortality and clinical signs. Body weights and food intake were recorded weekly. Ophthalmoscopic examinations were performed on all animals before the initiation of treatment and during Week 13. Blood and urine samples were collected during Week 4 and during Week 12 or 13. Following treatment, all animals were sacrificed and necropsied. Organ weights were recorded, and tissues were subjected to microscopic examination. No dose-related changes in mortality, clinical signs, body weights, body-weight gains, or food consumption were reported (data not shown). The researchers did not consider hematological variations (not further described) to be treatment-related. Aspartate aminotransferase (AST) levels were statistically significantly (p < 0.05) increased in females at doses of ≥5 mg/kg-day (data not shown). Increased urine levels, associated with a statistically (p < 0.05) significant decrease in specific gravity, were observed at ≥10 mg/kg-day (females) or 20 mg/kg-day (males) (data not shown). Although retinopathy was observed in some animals, a pathology peer review concluded that the incidence of these effects in the treatment groups was similar to the spontaneous incidence for Sprague-Dawley rats. At 20 mg/kg-day, an increased incidence of abnormally shaped pituitary glands was reported. The SCCP (2007) identified a NOAEL of 2.5 mg/kg-day for toluene-2,5-diamine sulfate in this study based on significantly elevated AST levels at 5 mg/kg-day. However, experimental data were not presented in the summary, and the adversity of the reported effects has not been demonstrated (there was no mention of the magnitude or dose-response of the observed change in AST, or corresponding changes in other serum enzymes or liver pathology). The available description of this study lacked information to support independent evaluation of the study.

The apparent NOAEL of 2.5 mg/kg-day and LOAEL of 5 mg/kg-day for increased serum AST levels in rats treated with toluene-2,5-diamine sulfate by gavage in water for 13 weeks (Hill, 1997, as cited in SCCP, 2007) can be used as the basis for derivation of screening provisional toxicity values for toluene-2,5-diamine sulfate and toluene-2,5-diamine. Based on available information, this appeared to be the most sensitive endpoint identified in the available studies. The choice of endpoint was supported by the results of the 14-day range-finding study, which reported changes in AST and other clinical chemistry measures at 30 mg/kg-day (Hill, 1994, as cited in SCCP, 2007).

Reproductive and developmental toxicity studies reported effects only at higher doses (80–160 mg/kg-day) (Kavlock et al., 1987; Seidenburg et al., 1986; Osterberg, 1982a,b, as cited in SCCP, 2007 and reviewed in Pang, 1992).

The critical effect identified in the U.S. EPA (2013) assessment for 2,5-TDA was increased serum aspartate aminotransferase (AST) in female rats exposed for 13 weeks (Hill, 1997). A no-observed-adverse-effect level (NOAEL) of 2.5 mg/kg-day for increased AST was selected as the POD in the screening subchronic p-RfD for 2,5-TDA sulfate (U.S. EPA, 2013). The corresponding POD for the free base is calculated by multiplying the POD for the sulfate by the ratio of the molecular weights (MW of 2,5-TDA as free base [122.17] ÷ MW of 2,5-TDA sulfate [220.25] = 0.55). The resulting NOAEL of 1.4 mg/kg-day for 2,5-TDA is adopted as the POD for deriving the screening subchronic p-RfD for 2,3-TDA. The NOAEL of 1.4 mg/kg-day is not adjusted for molecular-weight differences between 2,3- and 2,5-TDA (both as free base), because the molecular weights are identical.

The NOAEL of 1.4 mg/kg-day is converted to a human equivalent dose (HED) according to current (U.S. EPA, 2011c) guidance. In Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011c), the Agency endorses body-weight scaling to the 3/4 power (i.e., BW^3/4^) as a default to extrapolate toxicologically equivalent doses of orally administered agents from all laboratory animals to humans for the purpose of deriving an RfD from effects that are not portal-of-entry effects.

Following U.S. EPA (2011c) guidance, the POD for increased serum AST in female rats is converted to an HED through the application of a dosimetric adjustment factor (DAF) derived as follows:

DAF = ( BW_a_ 1 / 4 ÷ BW_h_ 1 / 4 )

where

DAF = dosimetric adjustment factor BW_a_ = animal body weight BW_h_ = human body weight

Using a reference BW_a_ of 0.204 kg for female Sprague Dawley rats in a subchronic study and a reference BW_h_ of 70 kg for humans (U.S. EPA, 1988), the resulting DAF is 0.23. Applying this DAF to the NOAEL of 1.4 mg/kg-day yields a POD (HED) as follows:

POD ( HED ) = NOAEL ( mg/kg-day ) × DAF = 1.4 mg/kg-day × 0.23 = 0.32 mg/kg-day

In deriving a screening p-RfD for 2,3-TDA, a composite uncertainty factor (UF_C_) of 300 is applied, based on a 3-fold uncertainty factor value for interspecies extrapolation (interspecies uncertainty factor [UF_A_], reflecting use of a dosimetric adjustment) and 10-fold uncertainty factor values for both intraspecies variability (UF_H_) and database deficiencies (database uncertainty factor [UF_D_], reflecting lack of adequate repeated-dose toxicity information for 2,3-TDA). The screening subchronic p-RfD for 2,3-TDA is derived as follows:

Screening Subchronic p-RfD = Analogue POD ( HED ) ÷ UF_C_ = 0.32 mg/kg-day ÷ 300 = 1 × 10^− 3^ mg/kg-day

Table A-7 summarizes the uncertainty factors for the screening subchronic p-RfD for 2,3-TDA.

Table A-7 Uncertainty Factors for the Screening Subchronic p-RfD for 2,3-Toluenediamine (CASRN 2687-25-4)

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^) is applied to account for residual uncertainty, including toxicodynamic differences, between rats and humans following 2,3-TDA exposure. The toxicokinetic uncertainty has been accounted for by calculation of an HED through application of a DAF in extrapolating from animals to humans (U.S. EPA, 2011c).
UF_D_ | 10 | A UF_D_ of 10 is applied owing to the absence of adequate repeated-dose toxicity studies for 2,3-TDA alone and the use of a read-across approach to derive the screening p-RfD.
UF_H_ | 10 | A UF_H_ of 10 is applied for interindividual variability to account for human-to-human variability in susceptibility in the absence of quantitative information to assess the toxicokinetics and toxicodynamics of 2,3-TDA in humans.
UF_L_ | 1 | A UF_L_ of 1 is applied for LOAEL-to-NOAEL extrapolation because the POD is a NOAEL.
UF_S_ | 1 | A UF_S_ of 1 is applied because a subchronic study was selected as the principal study.
UF_C_ | 300 | Composite UF = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_.

DAF = dosimetric adjustment factor; HED = human equivalent dose; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; POD = point of departure; p-RfD = provisional reference dose; TDA = toluenediamine; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

### Derivation of a Screening Chronic Provisional Reference Dose

2,5-TDA is also selected as the most appropriate analogue for 2,3-TDA for deriving the screening chronic p-RfD. U.S. EPA (2013) used the critical effect of increased AST levels in female rats and associated POD of 2.5 mg/kg-day (HED of 0.32 mg/kg-day estimated for this assessment) identified in the 13-week rat study (Hill, 1997) to derive a screening chronic p-RfD for 2,5-TDA. The principal study and calculation of the POD (HED) is described above. Although a cancer bioassay in rats and mice exposed to 2,5-TDA for 78 weeks was available (NTP, 1978), the U.S. EPA (2013) assessment concluded that the study was inadequate in scope and design for evaluating noncancer oral toxicity based on the following: (1) evaluations were limited to measures of body weight, food consumption, clinical signs, and non-neoplastic histopathology; (2) histopathological examinations were conducted after a lengthy recovery period (28–31 weeks); and (3) treatment was initiated at different times for the low- and high-dose groups (~11 months apart).

In deriving the screening chronic p-RfD for 2,3-TDA, the POD (HED) of 0.32 mg/kg-day from the 13-week rat study with 2,5-TDA is selected, applying an additional uncertainty factor of 10 to account for increased uncertainty associated with extrapolating from a subchronic to a chronic exposure (UF_S_). A UF_C_ of 3,000 was derived, reflecting a 3-fold UF_A_, and 10-fold uncertainty factor values for UF_H_, UF_S_, and UF_D_. Finally, the screening chronic p-RfD for 2,3-TDA is derived as follows:

Screening Chronic p-RfD = Analogue POD ( HED ) ÷ UF_C_ = 0.32 mg/kg-day ÷ 300 = 1 × 10^− 4^ mg/kg-day

Table A-8 summarizes the uncertainty factors for the screening chronic p-RfD for 2,3-TDA.

Table A-8 Uncertainty Factors for the Screening Chronic p-RfD for 2,3-Toluenediamine (CASRN 2687-25-4)

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^) is applied to account for residual uncertainty, including toxicodynamic differences, between rats and humans following 2,3-TDA exposure. The toxicokinetic uncertainty has been accounted for by calculation of an HED through application of a DAF in extrapolating from animals to humans (U.S. EPA, 2011c).
UF_D_ | 10 | A UF_D_ of 10 is applied owing to the absence of adequate repeated-dose toxicity studies for 2,3-TDA alone and the use of a read-across approach to derive the screening p-RfD.
UF_H_ | 10 | A UF_H_ of 10 is applied for interindividual variability to account for human-to-human variability in susceptibility in the absence of quantitative information to assess the toxicokinetics and toxicodynamics of 2,3-TDA in humans.
UF_L_ | 1 | A UF_L_ of 1 is applied for LOAEL-to-NOAEL extrapolation because the POD is a NOAEL.
UF_S_ | 10 | A UF_S_ of 10 is applied because a subchronic study was selected as the principal study.
UF_C_ | 3,000 | Composite UF = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_.

DAF = dosimetric adjustment factor; HED = human equivalent dose; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; POD = point of departure; p-RfD = provisional reference dose; TDA = toluenediamine; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.