# REFERENCES

Ahrens L. (2011). Polyfluoroalkyl compounds in the aquatic environment: a review of their occurrence and fate [Review]. J Environ Monit 13: 20–31. 10.1039/c0em00373e.21031178
Bailey SA; Zidell RH; Perry RW. (2004). Relationships between organ weight and body/brain weight in the rat: What is the best analytical endpoint? Toxicol Pathol 32: 448–466. 10.1080/01926230490465874.15204968
Bannach-Brown A; Przybyła P; Thomas J; Rice AS C; Ananiadou S; Liao J; Macleod MR. (2018). Machine learning algorithms for systematic review: reducing workload in a preclinical review of animal studies and reducing human screening error (pp. 1–26). bioRxiv. 10.1101/255760.
Beach SA; Newsted JL; Coady K; Giesy JP. (2006). Ecotoxicological evaluation of perfluorooctanesulfonate (PFOS) [Review]. Rev Environ Contam Toxicol 186: 133–174. 10.1007/0-387-32883-1_5.16676904
Boone L; Meyer D; Cusick P; Ennulat D; Bolliger AP; Everds N; Meador V; Elliott G; Honor D; Bounous D; Jordan H. (2005). Selection and interpretation of clinical pathology indicators of hepatic injury in preclinical studies [Review]. Vet Clin Pathol 34: 182–188. 10.1111/j.1939-165X.2005.tb00041.x.16134065
Buck RC; Franklin J; Berger U; Conder JM; Cousins IT; de Voogt P; Jensen AA; Kannan K; Mabury SA; van Leeuwen SP. (2011). Perfluoroalkyl and polyfluoroalkyl substances in the environment: terminology, classification, and origins [Review]. Integr Environ Assess Manag 7: 513–541. 10.1002/ieam.258.21793199
Calafat AM; Kato K; Hubbard K; Jia T; Botelho JC; Wong LY. (2019). Legacy and alternative per- and polyfluoroalkyl substances in the U.S. general population: Paired serum-urine data from the 2013–2014 National Health and Nutrition Examination Survey. Environ Int 131: 105048. 10.1016/j.envint.2019.105048.31376596
Calafat AM; Wong LY; Kuklenyik Z; Reidy JA; Needham LL. (2007). Polyfluoroalkyl chemicals in the US population: Data from the National Health and Nutrition Examination Survey (NHANES) 2003–2004 and comparisons with NHANES 1999–2000. Environ Health Perspect 115: 1596–1602. 10.1289/ehp.10598.18007991
Carlson LA; Angrish M; Shirke AV; Radke EG; Schulz B; Kraft A; Judson R; Patlewicz G; Blain R; Lin C; Vetter N; Lemeris C; Hartman P; Hubbard H; Arzuaga X; Davis A; Dishaw LV; Druwe IL; Hollinger H; Jones R; Kaiser JP; Lizarraga L; Noyes PD; Taylor M; Shapiro AJ; Williams AJ; Thayer KA. (2022). Systematic evidence map for over one hundred and fifty per- and polyfluoroalkyl substances (PFAS) [Review]. Environ Health Perspect 130: 56001. 10.1289/EHP10343.35580034
CERI (Chemicals Evaluation and Research Institute, Japan). (2002a). Bacterial reverse mutation test of T-7701. (3M-MPCA-00215756; K01–2703). Japan: Sumitomo 3M Limited.
CERI (Chemicals Evaluation and Research Institute, Japan). (2002b). Chromosomal aberration test of T-7701 using cultured mammalian cells. (3M-MPCA-00215776; K06–0937). Japan: Sumitomo 3M Limited.
CERI (Chemicals Evaluation and Research Institute, Japan). (2002c). Twenty-eight-day repeated-dose oral toxicity study of T-7701 in rats. (3M-MPCA-00215660; B11–0691). Japan: Sumitomo 3M Limited.
Cohen AM; Hersh WR; Peterson K; Yen PY. (2006). Reducing workload in systematic review preparation using automated citation classification. J Am Med Inform Assoc 13: 206–219. 10.1197/jamia.M1929.16357352
DeWitt JC. (2015). Toxicological effects of perfluoroalkyl and polyfluoroalkyl substances. New York, NY: Springer International. 10.1007/978-3-319-15518-0.
Duan Y; Sun H; Yao Y; Meng Y; Li Y. (2020). Distribution of novel and legacy per-/polyfluoroalkyl substances in serum and its associations with two glycemic biomarkers among Chinese adult men and women with normal blood glucose levels. Environ Int 134: 105295. 10.1016/j.envint.2019.105295.31726357
ECHA (European Chemicals Agency). (2020). Information on Chemicals [Database]. Helsinki, Finland: European Chemicals Agency, European Union. Retrieved from https://echa.europa.eu/information-on-chemicals
EMEA (European Medicines Agency). (2008). Non-clinical guideline on drug induced hepatotoxicity. (Doc. Ref. EMEA/CHMP/SWP/150115/2006). London, UK. http://www.ema.europa.eu/docs/en_GB/document_library/Scientific_guideline/2009/09/WC500003355.pdf.
Evidence Partners. (2022). DistillerSR. Retrieved from https://www.evidencepartners.com/products/distillersr-systematic-review-software/
Fenton SE; Ducatman A; Boobis A; DeWitt JC; Lau C; Ng C; Smith JS; Roberts SM. (2021). Per- and polyfluoroalkyl substance toxicity and human health review: Current state of knowledge and strategies for informing future research [Review]. Environ Toxicol Chem 40: 606–630. 10.1002/etc.4890.33017053
Hall AP; Elcombe CR; Foster JR; Harada T; Kaufmann W; Knippel A; Küttler K; Malarkey DE; Maronpot RR; Nishikawa A; Nolte T; Schulte A; Strauss V; York MJ. (2012). Liver hypertrophy: a review of adaptive (adverse and non-adverse) changes--conclusions from the 3rd International ESTP Expert Workshop [Review]. Toxicol Pathol 40: 971–994. 10.1177/0192623312448935.22723046
Hekster FM; Laane RW P M; de Voogt, P. (2003). Environmental and toxicity effects of perfluoroalkylated substances [Review]. In GW Ware (Ed.), Reviews of environmental contamination and toxicology: Continuation of residue reviews (pp. 99–121). New York, NY: Springer-Verlag. 10.1007/0-387-21731-2_4.
Howard BE; Phillips J; Miller K; Tandon A; Mav D; Shah MR; Holmgren S; Pelch KE; Walker V; Rooney AA; Macleod M; Shah RR; Thayer K. (2016). SWIFT-Review: A text-mining workbench for systematic review. Syst Rev 5: 87. 10.1186/s13643-016-0263-z.27216467
Howard BE; Phillips J; Tandon A; Maharana A; Elmore R; Mav D; Sedykh A; Thayer K; Merrick BA; Walker V; Rooney A; Shah RR. (2020). SWIFT-Active Screener: Accelerated document screening through active learning and integrated recall estimation. Environ Int 138: 105623. 10.1016/j.envint.2020.105623.32203803
Li Y; Cheng Y; Xie Z; Zeng F. (2017). Perfluorinated alkyl substances in serum of the southern Chinese general population and potential impact on thyroid hormones. Sci Rep 7: 43380. 10.1038/srep43380.28240244
Magnuson K; Cawley M; Reilly D; Varghese A. (2018). Improving efficiency of systematic reviews through machine learning for automated record deduplication and text analytics for iterative keyword streamlining. Poster presented at Society of Toxicology 57th Annual Meeting and ToxExpo, March 11–15, San Antonio, Texas.
NASEM (National Academies of Sciences, Engineering, and Medicine). (2018). Progress toward transforming the Integrated Risk Information System (IRIS) program: A 2018 evaluation. Washington, DC: National Academies Press. 10.17226/25086.
NASEM (National Academies of Sciences, Engineering, and Medicine). (2021). Review of U.S. EPA's ORD staff handbook for developing IRIS assessments: 2020 version. Washington, DC: National Academies Press. 10.17226/26289.
Pelch KE; Reade A; Wolffe TA M; Kwiatkowski CF. (2019). PFAS health effects database: Protocol for a systematic evidence map [Review]. Environ Int 130: 104851. 10.1016/j.envint.2019.05.045.31284092
PFASToxDatabase, T, he Endocrine Disruption Exchange. PFAS systematic evidence map. PFASToxDatabase, The Endocrine Disruption Exchange. https://pfastoxdatabase.org/.
Radke E; Wright MJ; Christensen K; Lin CJ; Goldstone AE; Glenn B; Thayer K. (2022). Epidemiology evidence for health effects of 150 per- and polyfluoroalkyl substances: A systematic evidence map [Review]. Environ Health Perspect 130: 96003. 10.1289/EHP11185.36178797
Radke EG; Braun JM; Meeker JD; Cooper GS. (2018). Phthalate exposure and male reproductive outcomes: A systematic review of the human epidemiological evidence [Review]. Environ Int 121: 764–793. 10.1016/j.envint.2018.07.029.30336412
Sciome (Sciome, LLC.). (2021). SWIFT-Active Screener. Available online at https://www.sciome.com/swift-activescreener/
Song X; Tang S; Zhu H; Chen Z; Zang Z; Zhang Y; Niu X; Wang X; Yin H; Zeng F; He C. (2018). Biomonitoring PFAAs in blood and semen samples: Investigation of a potential link between PFAAs exposure and semen mobility in China. Environ Int 113: 50–54. 10.1016/j.envint.2018.01.010.29421407
Sunderland EM; Hu XC; Dassuncao C; Tokranov AK; Wagner CC; Allen JG. (2019). A review of the pathways of human exposure to poly- and perfluoroalkyl substances (PFASs) and present understanding of health effects [Review]. J Expo Sci Environ Epidemiol 29: 131–147. 10.1038/s41370-018-0094-1.30470793
Tableau Software, LLC,. (2023). Tableau [Computer Program]. Retrieved from https://www.tableau.com/
U.S. EPA (U.S. Environmental Protection Agency). Health & Environmental Research Online (HERO). https://heronet.epa.gov/heronet/index.cfm/content/home.
U.S. EPA (U.S. Environmental Protection Agency). (1988). Recommendations for and documentation of biological values for use in risk assessment [EPA Report]. (EPA600687008). Cincinnati, OH. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=34855.
U.S. EPA (U.S. Environmental Protection Agency). (1994). Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry [EPA Report]. (EPA600890066F). Research Triangle Park, NC. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=71993&CFID=51174829&CFTOKEN=25006317.
U.S. EPA (U.S. Environmental Protection Agency). (2000). Supplementary guidance for conducting health risk assessment of chemical mixtures (pp. 1–209). (EPA/630/R-00/002). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=20533.
U.S. EPA (U.S. Environmental Protection Agency). (2002). A review of the reference dose and reference concentration processes. (EPA630P02002F). Washington, DC. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2005). Guidelines for carcinogen risk assessment [EPA Report]. (EPA630P03001F). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3-25-05.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2011). Recommended use of body weight 3/4 as the default method in derivation of the oral reference dose. (EPA100R110001). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/recommended-use-of-bw34.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2012). Benchmark dose technical guidance [EPA Report]. (EPA100R12001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/benchmark-dose-technical-guidance.
U.S. EPA (U.S. Environmental Protection Agency). (2018). Chemistry Dashboard. Washington, DC. Retrieved from https://comptox.epa.gov/dashboard
U.S. EPA (U.S. Environmental Protection Agency). (2019a). Nafion. https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/2811.
U.S. EPA (U.S. Environmental Protection Agency). (2019b). PFAS 150. https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/2826.
U.S. EPA (U.S. Environmental Protection Agency). (2020a). Benchmark Dose Software (BMDS). Version 3.2: User guide [EPA Report]. (EPA/600/R-20/216). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P10103T2.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2020b). ORD staff handbook for developing IRIS assessments (public comment draft) [EPA Report]. (EPA/600/R-20/137). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Center for Public Health and Environmental Assessment. https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=350086.
U.S. EPA (U.S. Environmental Protection Agency). (2020c). PFAS 150 (2020). https://hawc.epa.gov/assessment/100500085/.
U.S. EPA (U.S. Environmental Protection Agency). (2020d). PFAS 150 (2020) downloads. https://hawc.epa.gov/assessment/100500085/downloads/.
U.S. EPA (U.S. Environmental Protection Agency). (2021a). CompTox Chemicals Dashboard: Perfluoropropanoic acid 422-64-0 | DTXSID8059970. https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID8059970.
U.S. EPA (U.S. Environmental Protection Agency). (2021b). Health Assessment Workspace Collaborative (HAWC). https://hawc.epa.gov/portal/.
U.S. EPA (U.S. Environmental Protection Agency). (2021c). Human health toxicity values for hexafluoropropylene oxide (HFPO) dimer acid and its ammonium salt (CASRN 13252–13-6 and CASRN 62037–80-3). Also known as "GenX chemicals." Final report [EPA Report]. (EPA-822R-21–010). Washington, DC: U.S. Environmental Protection Agency, Office of Water.
U.S. EPA (U.S. Environmental Protection Agency). (2021d). Human health toxicity values for perfluorobutane sulfonic acid (CASRN 375–73-5) and related compound potassium perfluorobutane sulfonate (CASRN 29420–49-3) [EPA Report]. (EPA/600/R-20/345F). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=350888.
U.S. EPA (U.S. Environmental Protection Agency). (2021e). Toxicological review of perfluorobutanoic acid (PFBA) and related compound ammonium perfluorobutanoic acid (public comment and external review draft, Aug 2021) [EPA Report]. (EPA/635/R-20/424a). Washington, DC: U.S. Environmental Protection Agency, Integrated Risk Information System. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P1014IBF.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2022a). IRIS toxicological review of perfluorobutanoic acid (PFBA) and related salts. (EPA/635/R-22/277F).
U.S. EPA (U.S. Environmental Protection Agency). (2022b). ORD staff handbook for developing IRIS assessments [EPA Report]. (EPA 600/R-22/268). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Center for Public Health and Environmental Assessment. https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=356370.
Whalan JE. (2015). A toxicologist’s guide to clinical pathology in animals: Hematology, clinical chemistry, urinalysis. Switzerland: Springer International Publishing. 10.1007/978-3-319-15853-2.
Yost EE; Euling SY; Weaver JA; Beverly BE J; Keshava N; Mudipalli A; Arzuaga X; Blessinger T; Dishaw L; Hotchkiss A; Makris SL. (2019). Hazards of diisobutyl phthalate (DIBP) exposure: A systematic review of animal toxicology studies [Review]. Environ Int 125: 579–594. 10.1016/j.envint.2018.09.038.30591249