# PFPrA Quality Assurance

This work was conducted under the EPA Quality Program to ensure data are of known and acceptable quality to support their intended use. Surveillance of the work by the assessment managers and programmatic scientific leads ensured adherence to quality assurance (QA) processes and criteria and to quick and effective resolution of any problems. The QA manager, assessment managers, and programmatic scientific leads have determined this work meets all EPA quality requirements. This human health assessment was written with guidance from the Center for Public Health and Environmental Assessment (CPHEA) Program Quality Assurance Project Plan, the Quality Assurance Project Plan titled Umbrella Quality Assurance Project Plan for CPHEA Fit-For-Purpose Toxicity Assessments (L-CPAD-0033369-QP-1-2), and the contractor-led Quality Assurance Project Plan, General Support of CPHEA Assessment Activities (L-CPAD-0031961-QP-1-2). As part of the QA system, a quality product review is completed prior to management clearance. During assessment development, a Technical Systems Audit was performed on December 15, 2022, with no major findings.

This assessment received internal peer review by two EPA/ORD/CPHEA scientists and an independent, external peer review by three scientific experts outside of EPA. External peer review was managed by Eastern Research Group, Inc. (110 Hartwell Avenue Lexington, MA 02421) under contract EP-C-17-017. The reviews focused on whether studies were correctly selected and interpreted and adequately described for the purposes of this ORD assessment. The reviews also covered quantitative and qualitative aspects of the toxicity value development and addressed whether uncertainties associated with the assessment were adequately characterized.