# AUTHORS, CONTRIBUTORS, AND REVIEWERS

Chemical Managers/Authors
Jason C. Lambert, PhD, DABT | U.S. EPA, Center for Computational Toxicology and Exposure
Lucina Lizarraga, PhD | U.S. EPA, Center for Public Health and Environmental Assessment
Elizabeth Oesterling Owens, PhD | U.S. EPA, Center for Public Health and Environmental Assessment
Contributors
Avanti Shirke, MPH | U.S. EPA, Center for Public Health and Environmental Assessment
Christine Cai, MS
Elizabeth G. Radke, PhD
Production Support
Dahnish Shams; Jessica Soto-Hernandez; Ryan Jones; Samuel Thacker; Vicki Soto | U.S. EPA, Center for Public Health and Environmental Assessment
Lauren Johnson | Student Services Contractor, Oak Ridge Associated Universities (ORAU)
Primary Internal Reviewers
Andrew Kraft, PhD | U.S. EPA, Center for Public Health and Environmental Assessment
J. Allen Davis, MSPH
Primary External Reviewers^1^
Gloria B. Post, PhD, DABT | New Jersey Department of Environmental Protection
Panagiotis G. Georgopoulos, PhD | Rutgers University
Penelope A. Rice, PhD, DABT | U.S. Food and Drug Administration
Executive Direction
Wayne Cascio, MD; V. Kay Holt; Samantha Jones, PhD; Kristina Thayer, PhD | CPHEA Center Director; CPHEA Deputy Center Director; CPHEA Associate Director; CPHEA Chemical and Pollutant Assessment Division Director

Questions regarding the content of this assessment should be directed to the EPA Office of Research and Development (ORD) Center for Public Health and Environmental Assessment (CPHEA) website at https://ecomments.epa.gov/.

1 Dr. Post and Dr. Rice conducted this review as independent consultants and not as a representative of the New Jersey Department of Environmental Protection and the U.S. Food and Drug Administration, respectively.