# CARCINOGENICITY ASSESSMENT

No studies have been identified that examine potential carcinogenicity of PFPrA via any route of exposure.