# DERIVATION OF REFERENCE VALUES

The hazard and dose-response database for PFPrA is limited to studies via the oral route of exposure. There are no known inhalation or dermal studies for PFPrA. Further, no known studies have evaluated potential cancer effects of PFPrA, and studies relevant to potential cancer mechanism(s) are sparse and inconclusive. The purpose of this assessment is to inform human health hazard(s) associated with chronic duration/lifetime exposures to PFPrA. Therefore, only a noncancer chronic reference dose (RfD) is derived in this assessment for the oral route of exposure. The RfD derived in this assessment is an estimate of an oral exposure to the human population (including susceptible subgroups and lifestages) likely to be without an appreciable risk of adverse health effects over a lifetime.

## Derivation of Oral Reference Dose

The hazard and dose-response database for PFPrA is limited to one medium confidence (Duan et al., 2020) and two low confidence (Song et al., 2018; Li et al., 2017) epidemiological studies that evaluated potential associations between health effects and PFPrA blood serum concentrations in humans, and one high confidence repeat-dose (28-day) oral gavage study in rats [conducted by the Chemicals Evaluation and Research Institute, Japan; (CERI, 2002c)]. Two of the three human studies have multiple limitations discussed previously (see the Human Studies summaries for more details) that diminish confidence in reported associations and decrease their ability to inform conclusions. In addition, studies that used measurements of biomarkers in tissues or bodily fluids as the metric for exposure were considered suitable only for dose-response analysis if data or physiologically based pharmacokinetic (PBPK) models are available to extrapolate between the reported biomarker measurement and the route-specific level of exposure. As such, the human studies were not considered further for toxicity value derivation.

The 28-day oral rat study CERI (2002c) was conducted consistent with OECD guideline protocol and under GLP conditions and had an overall high confidence rating based on a study quality evaluation (see HAWC link (https://hawcprd.epa.gov/rob/study/101066812/) for more details). Male and female control and PFPrA-treated rats were evaluated across a comprehensive panel of general toxicity, clinical chemistry, organ weight, and histopathological parameters. The liver of rats was identified as a primary target of PFPrA toxicity following 28 days of oral exposure; male rats were more sensitive than females across all parameters evaluated and thus were prioritized for dose-response analyses. Alterations included increases in relative liver weights at ≥20 mg/kg-day and increased absolute liver weights in males at ≥80 mg/kg-day; gross enlargement of the liver and histopathological indicators of altered tissue architecture or injury (e.g., centrilobular hypertrophy; some evidence of focal necrosis) at ≥80 mg/kg-day; and increased serum enzymes indicative of hepatic injury (i.e., ALT and ALP) at ≥80 mg/kg-day. According to Hall et al. (2012), this constellation of effects is consistent with criteria supporting a determination of liver injury. Specifically, the PFPrA-induced liver effects are indicative of an interrelated pattern of toxicity to parenchymal (i.e., hepatocyte hypertrophy, necrosis, and ALT release into systemic circulation) and nonparenchymal (e.g., hepatic biliary epithelial release of ALP into systemic circulation) cell populations. Despite the lack of additional oral repeat-dose studies examining liver effects of PFPrA by which to evaluate similarity of results, this profile of PFPrA-induced liver effects is consistent with liver toxicity observed in experimental rodents following oral exposure to perfluorobutanoic acid, a closely related linear short-chain (4-carbon) perfluorocarboxylic acid (U.S. EPA, 2021e). These effects observed in animals are considered relevant for humans in the absence of experimental data that provide direct information to the contrary. In total, evidence in animals indicates that PFPrA exposure may cause liver effects in humans, but few studies were available to contribute to the evaluation. The main study that this conclusion is based on assessed dose levels of 5–320 mg/kg-day and was conducted according to well-established experimental animal guidelines (CERI, 2002c). Despite limitations in the availability of repeat-dose toxicity studies in the database (including in species other than rat), the 28-day rat study by CERI (2002c) was considered for the derivation of a chronic RfD for PFPrA. The RfD for PFPrA may be useful for certain decision contexts, such as providing a sense of the magnitude of potential human health risks, ranking potential hazards, or informing PFAS mixtures assessment in which PFPrA is a component (U.S. EPA, 2005, 2000).

The PFPrA-induced liver effects observed in male rats from the CERI (2002c) 28-day study were evaluated for amenability to benchmark dose (BMD) modeling (see Table 5). Consistent with EPA’s Benchmark Dose Technical Guidance (U.S. EPA, 2020a, 2012, 2002), the BMDs and 95% lower confidence limits on the BMDs (BMDLs) for increased relative liver weight, serum ALT, serum ALP, and incidence of hepatocyte hypertrophy were estimated using a benchmark response (BMR) representative of a biologically or statistically significant level of change for continuous (e.g., relative liver weight; serum ALT and ALP) or dichotomous (e.g., incidence of hepatocyte hypertrophy) endpoints. For liver weight changes, a 10% increase over control is considered biologically significant for this assessment. For serum ALT and ALP, a 1-standard deviation (SD) change over control was used. For hepatocyte hypertrophy, a 10% increased incidence over control was used (U.S. EPA, 2020a, 2012, 2002). The full results of the BMD modeling are provided in Appendix B.

Table 5 Data for Liver Effects in Adult Male Crj:CD (SD) IGS (SPF) Rats Exposed to PFPrA for 28 Days via Gavage (CERI, 2002c)

Endpoint | Dose, mg/kg-d^b^
| 0 | 5 | 20 | 80 | 320
Relative liver weight – % of BW^a^ | 3.15 ± 0.19 | 3.24 ± 0.21 (+3%) | 3.58 ± 0.34^*^ (+14%) | 3.92 ± 0.29^**^ (+24%) | 4.27 ± 0.43^**^ (+36%)
Serum ALT – IU/L^a^ | 25 ± 5 | 27 ± 3 (+8%) | 27 ± 2 (+8%) | 29 ± 4^**^ (+16%) | 35 ± 4 (40%)
Serum ALP – IU/L^a^ | 420 ± 48 | 428 ± 74 (+2%) | 242 ± 83 (+1%) | 545±79^**^ (+30%) | 518 ± 107 (23%)
Hepatocyte hypertrophy – incidence | 0 | ND | 0 | 2 | 6
Animals (n) | 6 | 6 | 6 | 6 | 6

ALT = alanine aminotransferase; ALP = alkaline phosphatase; BW = body weight; ND = not determined.

a Values expressed as mean ± SD. Parentheses show % change relative to control = ([treatment mean − control mean] ÷ control mean) × 100.

b Dosimetry: Oral rat exposures are expressed in mg/kg-day as reported by the study authors.

* Biologically significant change from control.

** Statistically (p ≤ 0.05) and biologically significant change from control.

Following dose-response modeling of the liver effect data in male rats, BMDLs were converted to corresponding human equivalent doses (HEDs) (see Table 6). In Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011), EPA endorses a hierarchy of approaches to derive human equivalent oral exposures from data on laboratory animal species, with the preferred approach being physiologically based toxicokinetic modeling. Without a complete physiologically based toxicokinetic model, other approaches might include using available chemical-specific information (e.g., clearance or plasma half-life values). In the absence of chemical-specific models or data to inform the derivation of human equivalent oral exposures, EPA recommends doses be scaled allometrically using body weight (BW)^3/4^ as a default method to extrapolate toxicologically equivalent doses of orally administered agents from laboratory animals to humans to derive an RfD, under certain exposure conditions. For PFPrA, no toxicokinetic data were identified, so no chemical-specific data are available to inform cross-species kinetics between rats and humans^4^. As such, the male rat BMDLs were converted to the human equivalent points of departure (POD_HEDs_) using default BW^3/4^ scaling. Table 6 provides the candidate points of departure (i.e., POD_HEDs_) obtained from the BMD-modeled liver effects data from male rats of the 28-day study (CERI, 2002c).

Table 6 Candidate PODs for Derivation of the Chronic RfD for PFPrA

Endpoint | BMDL mg/kg-d | POD type | POD_HED_^a^ mg/kg-d | Reference
Increased relative liver weight in adult males | 6.3 | BMDL_10_ | 1.6 | CERI (2002c)
Increased hepatocyte hypertrophy in adult males | 7.9 | BMDL_10_ | 2.0 | CERI (2002c)
Increased serum ALP in adult males | 20 | BMDL_1SD_ | 5.0 | CERI (2002c)
Increased serum ALT in adult males | 28 | BMDL_1SD_ | 7.0 | CERI (2002c)

ALP = alkaline phosphatase; ALT = alanine aminotransferase; BMDL = 95% lower confidence limit on the BMD (subscripts denote BMR: i.e., 10 = dose associated with a 10% extra risk in parameter, 1SD = dose associated with 1 standard deviation relative risk from the control); BMR = benchmark response; POD = point of departure; POD_HED_ = human equivalent point of departure.

a HEDs were calculated using species-specific application of a dosimetric adjustment factor (DAF), as recommended by U.S. EPA (2011). The DAFs are calculated as follows: DAF = (BW_a_^1/4^ ÷ BW_h_^1/4^), where BW_a_ = animal body weight, and BW_h_ = human body weight. Default body weight for male SD-derived rats (0.267 kg [for subchronic duration]) and a reference body weight of 80 kg for humans, as recommended in U.S. EPA (1988), were used to calculate the DAFs.

Considering that confidence among the candidate points of departure (PODs) is approximately equivalent (i.e., the same study population/species, exposure paradigm, and quality of exposure and outcome measurement), the POD_HED_ of 1.6 mg/kg-day for increased relative liver weight represented the most sensitive effect in rats and was identified as the POD for deriving a chronic RfD for oral PFPrA exposure. Under EPA’s A Review of the Reference Dose and Reference Concentration Processes (U.S. EPA, 2002) and Methods for Derivation of Inhalation Reference Concentrations and Application of Inhalation Dosimetry (U.S. EPA, 1994), five possible areas of uncertainty and variability were considered in deriving the chronic RfD for PFPrA. The chronic RfD is derived by applying a composite uncertainty factor (UF_C_) of 3,000 (reflecting an interspecies uncertainty factor [UF_A_] of 3, an intraspecies uncertainty factor [UF_H_] of 10, a duration uncertainty factor [UF_S_] of 10, and a database uncertainty factor [UF_D_] of 10) to the POD_HED_ of 1.6 mg/kg-day. Table 7 summarizes the uncertainty factors for the chronic RfD for PFPrA. Confidence in the chronic RfD for PFPrA is low, as described in Table 8. The low confidence in the chronic RfD, resulting primarily from the limited available hazard and dose-response relevant evidence in the database, indicate a high level of uncertainty in the derived RfD. Nevertheless, this RfD may be useful for some decision purposes (U.S. EPA, 2005).

Chronic RfD = POD_H E D_ ÷ UF_C_ = 1.6 mg/kg-day ÷ 3,000 = 0.0005 or 5 × 10^− 4^ mg/kg-day

Table 7 Uncertainty Factors for the Chronic RfD for PFPrA (CASRN 422-64-0)

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^) is applied to account for uncertainty in characterizing the toxicokinetic and toxicodynamic differences between animals and humans following oral PFPrA exposure. Cross-species dosimetric adjustment (HED calculation) was performed using default allometric BW^3/4^ scaling between rats and humans. This scaling is applied to account for some aspects of the cross-species toxicokinetic processes. Further, cross-species toxicokinetic (TK) data for PFBA, a closely related linear short-chain (4-carbon) perfluorocarboxylic acid, was considered. For PFBA, TK data exist in relevant animals and humans, leading to a data-informed extrapolation approach (i.e., ratio of the clearance (CL) in humans to animals, CL_H_:CL_A_) for estimating the DAF as suggested in U.S. EPA (2022a). For comparison purposes, for PFPrA, the DAF of 0.25 for male rats based on the application of the default (BW)^3/4^ approach is similar to the data-informed DAF for male rats for PFBA of 0.229. This suggests that although a default allometric BW scaling approach is used for the 3-carbon structure PFPrA, the resulting DAF is similar to a data-informed DAF for the 4-carbon PFBA. As such, a factor of 3 is applied to account for residual toxicokinetic uncertainty and potential toxicodynamic differences across species.
UF_D_ | 10 | A UF_D_ of 10 is applied to account for deficiencies and uncertainties in the database. The database for oral exposure to PFPrA is limited to three human epidemiological studies (one medium confidence and two low confidence) and a single high confidence, 28-day repeat-dose oral rat study. No longer-duration repeat-dose studies, examining potential systemic, reproductive, developmental or immunotoxicity effects are available following exposure via any route.
UF_H_ | 10 | A UF_H_ of 10 is applied to account for interindividual variability in the susceptibility of the human population because of both intrinsic and extrinsic factors that can influence the response to dose, in the absence of chemical-specific information to assess toxicokinetic and toxicodynamic variability of PFPrA in humans.
UF_L_ | 1 | A UF_L_ of 1 is applied because the POD is a BMDL.
UF_S_ | 10 | A UF_S_ of 10 is applied to account for uncertainty in how a significantly longer exposure duration might impact the incidence and or severity of liver injury. The POD was derived from a 28-day rat study; studies of PFPrA exposures for longer than 28 days were not available to evaluate and characterize the potential for increasing magnitude or incidence of injury in the liver with increasing exposure duration.
UF_C_ | 3,000 | Composite UF = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_.

BMDL = benchmark dose lower confidence limit; BW = body weight; HED = human equivalent dose; POD = point of departure; RfD = reference dose; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = less-than-chronic duration uncertainty factor.

Table 8 Confidence Descriptors for the Chronic RfD for PFPrA (CASRN 422-64-0)

Confidence Categories | Designation | Discussion
Confidence in study | H | Confidence in the principal study CERI (2002c) is high. The study was performed by an industry/contract lab using an established OECD protocol for 28-day oral exposures in rodents and under GLP conditions. All but one of the toxicity study rating criteria were of “Good” or “High” confidence (see Figure 3 and information available on HAWC (https://hawc.epa.gov/summary/visual/assessment/100500281/RoB-Heatmap-CERI-2002-8728368/)).
Confidence in database | L | Confidence in the database for PFPrA is low. The relevant human health assessment database consists of one medium and two low confidence human epidemiological studies, and a single 28-day repeat-dose oral rat study. No longer-duration repeat-dose studies, examining potential systemic, reproductive, developmental or immunotoxicity effects are available following exposure via any route.
Confidence in quantification of the POD_HED_ | M | Confidence in the quantification of the POD and RfD is medium. The POD was based on BMD modeling within the range of the observed data. Dosimetric adjustment of the POD was based on default BW^3/4^ scaling due to the lack of chemical specific toxicokinetic data (e.g., clearance, half-life).
Confidence in the chronic RfD | L | The overall confidence in the chronic RfD is low and is primarily driven by low confidence in the available database for PFPrA.

BMD = benchmark dose; BW = body weight; GLP = Good Laboratory Practice; HED = human equivalent dose; POD = point of departure; RfD = reference dose.

## Derivation of Inhalation Reference Concentrations

No studies have been identified that examine noncancer effects of PFPrA via the inhalation exposure route.

## Summary of Noncancer Reference Values

Noncancer reference values are summarized in Table 9.

Table 9 Summary of the Noncancer Reference Values for PFPrA (CASRN 422-64-0)

Toxicity Type (units) | Species/Sex | Critical Effect | Reference Value mg/kg-d | POD Method | POD_HED_ mg/kg-d | UF_C_ | Principal Study
Chronic RfD (mg/kg-d) | Rat/M | Increased relative liver weight | 0.0005 | BMDL_10_ | 1.6 | 3,000 | CERI (2002c)
Chronic RfC (mg/m^3^) | NDr

BMDL = benchmark dose lower confidence limit (subscripts denote benchmark response: i.e., 10 = dose associated with a 10% extra risk in parameter); M = male(s); NDr = not derived; POD_HED_ = human equivalent point of departure; RfC = reference concentration; RfD = reference dose; UF_C_ = composite uncertainty factor.

4 To inform cross-species extrapolation for PFPrA, toxicokinetic (TK) data for PFBA, a closely related linear short-chain (4-carbon) perfluorocarboxylic acid, was considered. For PFBA, TK data exist in relevant animals and humans, leading to a data-informed extrapolation approach (i.e., ratio of the clearance (CL) in humans to animals, CL_H_:CL_A_) for estimating the DAF in U.S. EPA (2021e). For comparison, the DAF for PFPrA, based on the default (BW)^3/4^ approach in male rats, is 0.25 which is similar to the data-informed DAF for male rats for PFBA of 0.229.