# RESULTS

## Literature Search and Screening Results

The database searches yielded 352 unique references for PFPrA. As shown in Figure 1, three human, one animal, and two genotoxicity studies from the 352 initial references with information relevant to understanding the potential health effects of PFPrA were identified.

Figure 1 PFPrA Literature Search Flow Diagram

PFPrA Literature Search Flow Diagram

### Human Studies

Three studies (Duan et al., 2020; Song et al., 2018; Li et al., 2017) examining associations of health effects with PFPrA blood concentrations in humans were identified (see Table 2). All three studies were general population cross-sectional analyses conducted in China. Adults were the primary subject in each case; a portion of the study sample in Li et al. (2017) was younger than 18 years, but the authors did not conduct sub-analyses by lifestage. One study was rated at an overall medium confidence (Duan et al., 2020), and two were rated low confidence (Song et al., 2018; Li et al., 2017) (see Figure 2 and HAWC link (https://hawc.epa.gov/summary/visual/assessment/100500281/PFPA-Human-Study-Quality-Evaluations-All-Health/) for details on study confidence ratings). All three studies were rated as deficient for study sensitivity due to narrow concentration contrasts (Duan et al., 2020; Song et al., 2018; Li et al., 2017) or small sample size (Duan et al., 2020; Song et al., 2018; Li et al., 2017), so null findings should not be interpreted as evidence of no effect. Further details on the specific studies, concentration measurements, and chemicals evaluated are available in the interactive HAWC link (https://hawc.epa.gov/summary/visual/assessment/100500281/PFPA-Human-Study-Quality-Evaluations-All-Health/).

#### Specific Studies

##### Duan et al. (2020)

One medium confidence cross-sectional study of nondiabetic Chinese adults examined the association between serum PFPrA concentrations and glycemic indicators (Duan et al., 2020). Participants provided an overnight fasting blood sample. Serum fasting glucose and HbA1c (a form of hemoglobin linked to sugar and a biomarker for prediabetes or type 2 diabetes) were measured. Concurrent measurement of serum PFPrA concentrations and outcome was considered adequate due to the potential for short-term responses in these outcomes. In unadjusted linear regression models, serum PFPrA was significantly associated with decreasing HbA1c levels. After adjustment for potential confounders (sex, age, body mass index, smoking and alcohol use, exercise, education, and family history of diabetes), however, the effect was no longer significant (β [95% confidence interval]: −0.012 [−0.026, 0.002]). A significant interaction (p-interaction = 0.024) with body mass index was observed for the association between serum PFPrA levels and HbA1c. When stratified by age (<55 and ≥55 years), the association for HbA1c was not significant for either group, although the direction of effect was similar to that of the combined analysis. The association for fasting glucose was in the same direction as for HbA1c but was not statistically significant before or after adjustment. The biological significance of decreasing HbA1c levels in association with serum PFPrA concentrations is unclear.

##### Li et al. (2017)

One low confidence cross-sectional study examined the association between PFPrA concentrations and thyroid hormones (Li et al., 2017). Adult and child participants with normal thyroid function and with thyroid disease (i.e., hyperthyroidism, hypothyroidism, and Hashimoto’s disease) in China provided serum samples for analysis of PFAS and thyroid hormones. The analysis included thyroid stimulating hormone (TSH), free thyroxine (FT4), free triiodothyronine (FT3), thyroglobulin antibody (TGAb), and thyroid microsomal antibody (TMAb). This study was low confidence due to multiple concerns for risk of bias. Details on recruitment and participation were limited, and, for those participants without thyroid disease, the reason for presentation to the hospital was not clear. Potential confounding by socioeconomic status and other factors was a concern. Additionally, timing of outcome assessment was unaccounted for in the analysis or design. Inconsistent timing of outcome assessment could lead to outcome misclassification due to the diurnal variations in thyroid hormones. Bivariate correlations of PFPrA concentrations and thyroid hormones and antibodies revealed no statistically significant associations (all correlation coefficients ranged from −0.05 to −0.1, except for FT3 in participants with hypothyroidism, r = 0.4). Only statistically significant associations were carried forward to linear regression analysis, which included adjustment for confounding. Quantitative results for multivariable linear regression were not reported for PFPrA due to lack of statistical significance.

##### Song et al. (2018)

One low confidence cross-sectional study examined the association between PFPrA concentrations and semen parameters (Song et al., 2018). Men at an infertility clinic in China were recruited; reasons for visiting the infertility clinic were not provided, but only men without genital damage, venereal disease, or azoospermia were included in the study. The association between PFPrA concentrations and semen parameters was examined separately for PFPrA concentrations in serum and semen. This study was low confidence due to lack of adjustment for potential confounders and limited information on participant selection and semen collection and analysis. No statistically significant effects were identified for semen quality parameters using concentrations from either biomonitoring matrix, and the direction of association was inconsistent in serum and semen for both sperm motility and concentration.

#### Summary

In summary, evidence on the health effects of PFPrA in human epidemiological studies is limited. No clear associations were observed with glycemic indicators, thyroid hormones, or semen parameters. No effects of PFPrA concentrations were reliably identified in the available human studies; due to poor sensitivity across the available studies, however, this should not be interpreted as evidence of no effect.

Table 2 Associations Between PFPrA Concentrations and Health Effects in Human Epidemiological Studies

Reference, Confidence | Location, Years | Design | Population Ages (N) | Concentration Matrix and Levels (ng/mL) | Outcome | Comparison | Select Results^a^
General Population
Duan et al. (2020); Medium (see HAWC link (https://hawc.epa.gov/rob/study/101156700/) for details) | China, 2017 | Cross-sectional | Adults; 19–87 years old; (N = 252) | Serum; Median (25th–75th percentile): 0.48 ng/mL (0.24–0.82), 23% BLOD | Fasting glucose (nmol/L), HbA1c (%) | Regression coefficient (per 1% increase serum PFPrA) | Glucose (fasting):; −0.007 (−0.021, 0.008); p-value = 0.380; HbA1c:; −0.012 (−0.026, 0.002); p-value = 0.099
Li et al. (2017); Low (see HAWC link (https://hawc.epa.gov/rob/study/101156697/) for details) | China, 2013–2014 | Cross-sectional | Children to adults; 1 month–90 years old; (N = 202) | Serum; 91% above LOD; Median (min-max): 0.16 ng/mL (<LOD–6.1), 9% BLOD | FT3, FT4, TSH, TGAb, TMAb | Pearson correlation coefficients | Total study population:; FT3: 0.027; FT4: 0.032; TSH: −0.042; TGAb: 0.001; TMAb: −0.013; Quantitative multivariable results not reported, stated as p > 0.05
Song et al. (2018); Low (see HAWC link (https://hawc.epa.gov/rob/study/101156699/) for details) | China, 2012–2013 | Cross-sectional | Men; (N = 103) | Median; (5th–95th percentile); Serum:; 0.62 ng/mL (0.21–2.1); Semen:; 0.95 ng/mL (0.29–4.1); 0% BLOD in both matrices | Semen concentration (10^6^/mL), progressive motility (%) | Spearman correlation coefficients | Semen concentration,; Serum: −0.112; Semen: 0.114; Progressive motility,; Serum: 0.176; Semen: −0.180

BLOD = below the limit of detection; FT3 = free triiodothyronine; FT4 = free thyroxine; HbA1c = form of hemoglobin linked to sugar; LOD = limit of detection; TGAb = thyroglobulin antibody; TMAb = thyroid microsomal antibody; TSH = thyroid stimulating hormone.

a Results reported as effect estimate (95% confidence interval) unless otherwise specified. In some cases, presented results are constrained to those models or comparisons that most fully addressed major sources of potential bias.

Figure 2 Summary of Study Evaluation for Human Epidemiological Studies of PFPrA and All Health Outcomes

Interactive figure and additional study details available on HAWC (https://hawc.epa.gov/summary/visual/assessment/100500281/PFPA-Human-Study-Quality-Evaluations-All-Health/).

Summary of Study Evaluation for Human Epidemiological Studies of PFPrA and All Health Outcomes

### Animal Studies

A single repeat dose study is available that evaluates the toxicity of PFPrA after oral exposure (CERI, 2002c) (see Table 3). The available study is a 28-day exposure in 5-week-old male and female Crj:CD (SD) IGS rats (SPF). To determine a dose range for the 28-day study, a 14-day study was first performed that included doses of 50, 250, or 1,000 mg/kg-day. Effects on hematological parameters and organ weights were found in all dose groups after 14 days of oral exposure. Clinical chemistry abnormalities and necropsy findings were reported in the mid- and high-dose groups and clinical signs of toxicity, changes in body weights, and histopathology were reported in the high-dose group. No other details regarding the 14-day study design (e.g., number and sex of the animals) methods of endpoint evaluation, or quantitative exposure-response data were provided. The results of the 14-day study informed the authors’ selection of doses for the 28-day study: Male and female rats (n = 6 per dose group and sex) were exposed via daily oral gavage to 0, 5, 20, 80, or 320 mg/kg-day PFPrA in water for 28 consecutive days. Additional control and high-dose animals were maintained for a 14-day recovery period. The study was conducted according to Organization for Economic Cooperation and Development (OECD) and Good Laboratory Practice (GLP) guidelines and evaluated clinical signs, body weights, food intake, hematology, blood chemistry, urinalysis, organ weights (liver, kidneys, testes, ovaries, brain, spleen, adrenals) and histopathology (forestomach, glandular stomach, intestine [duodenum, jejunum, ileum, cecum, colon, rectum], liver, heart, kidneys, spleen, adrenals). Confidence is high in the study for all endpoints evaluated, with no significant concerns for potential bias or insensitivity (see Figure 3).

Figure 3 Summary of Study Evaluation for Experimental Animal Toxicological Studies of PFPrA and All Health Outcomes

Interactive figure and additional study details available on HAWC (https://hawcprd.epa.gov/summary/visual/assessment/100500281/RoB-Heatmap-CERI-2002-8728368/).

Summary of Study Evaluation for Experimental Animal Toxicological Studies of PFPrA and All Health Outcomes

No significant effects on body weight or food intake were reported in rats with doses up to 320 mg/kg-day. Clinical signs of toxicity occurred in both males and females at the high dose and included decreased movement (8/12 males and 4/12 females) and increased salivation (9/12 males and 6/12 females). The salivation was noted to occur right after dosing and was associated with mucosal irritation and hyperplasia of squamous epithelium in the limiting ridge of the forestomach in females (4/6 animals). Loss of hair and exude/scab formation were observed in 1/6 males in the 5 and 80 mg/kg-day dose groups.

Dose-related increases in liver weights (absolute and relative) were reported in male rats (see Figure 4). Relative liver weight, the preferred metric for this organ based on its proportional relationship to body weight (Bailey et al., 2004), increased 14%–36% at ≥20 mg/kg-day in males, reaching statistical significance at 80 and 320 mg/kg-day. Marginal, non-statistically significant increases in relative liver weight were observed in the females of the same dose groups (7% and 9% at 80 and 320 mg/kg-day, respectively). Increased relative liver weights persisted after the recovery period in the 320 mg/kg-day males.

Figure 4 Liver Weight Changes in Rats Following Oral Expose to PFPrA

Interactive figure available on HAWC (https://hawcprd.epa.gov/summary/data-pivot/assessment/100500281/PFPA-Liver-Weights-effect-size-animal/).

Liver Weight Changes in Rats Following Oral Expose to PFPrA

The liver weight increases in males were accompanied by noticeable enlargement of the liver at necropsy in the 320 mg/kg-day dose group and increased incidence of centrilobular hypertrophy (slight to moderate severity) at the two highest doses (2/6 and 6/6 animals at 80 and 320 mg/kg-day, respectively) (see Figure 5). Slight, focal necrosis was observed in 1/6 males in both the 20 and 80 mg/kg-day dose groups. These liver lesions were not observed in the controls or in females (0, 20, 80 and 320 mg/kg-day dose groups were evaluated in males and 0 and 320 mg/kg-day dose groups were evaluated in females for liver histopathology). Livers were no longer visibly enlarged nor were any microscopic lesions noted in males following the 14-day recovery period.

Figure 5 Liver Histopathology in Rats Following Oral Expose to PFPrA

Interactive figure available on HAWC (https://hawc.epa.gov/summary/data-pivot/assessment/100500281/PFPA-Liver-Histopathology-effect-size-animal/).

Liver Histopathology in Rats Following Oral Expose to PFPrA

Serum enzyme levels were also examined in the 28-day rat study (CERI, 2002c) (see HAWC figure (https://hawc.epa.gov/summary/data-pivot/assessment/100500281/PFPA-Liver-Serum-Markers-effect-size-animal/) for more details). Alanine aminotransferase (ALT) and aspartate aminotransferase (AST) are markers of hepatocellular damage, while alkaline phosphatase (ALP) and gamma-glutamyl transferase (GGT) are markers of hepatobiliary damage (Hall et al., 2012; EMEA, 2008; Boone et al., 2005). In males, ALT and ALP levels showed an increasing trend (p < 0.05) across dose groups, reaching statistical significance at the highest dose (40% at 320 mg/kg-day) for ALT and at 80 mg/kg-day (30%) for ALP. Levels of AST and GGT were not significantly elevated in either male or female rats. Effects in other clinical markers relevant to liver function were also reported. Blood proteins such as albumin and globulin are routinely evaluated in clinical chemistry and changes in the levels of these blood proteins can be indicators of kidney or liver damage (Whalan, 2015). The albumin/globulin (A/G) ratio was significantly increased in all dose groups in males (15%–25%), and albumin levels were slightly elevated in the high-dose male group (4%); the increases in albumin and A/G ratio displayed a significant trend. Significant decreases in total bilirubin occurred in males (33% in all dose groups) and in females (44% at doses ≥80 mg/kg-day), but the biological significance of this decrease is unclear. Although results were not always coherent across endpoints, changes in some serum markers provide support for potential liver damage in PFPrA-exposed animals (i.e., increased ALT and ALP, and possibly A/G ratio).

Other health effects were observed in rats after 28 days of exposure, but they generally occurred only at the highest dose, were sporadic, or were not supported by corroborative evidence of toxicity. For example, kidney weight changes were observed in male and female rats but were not accompanied by significant histological lesions or biochemical indicators of kidney toxicity in the blood or urine. Indeed, female absolute kidney weights were significantly increased (p < 0.05) in the 80 mg/kg-day group only (16%), with a 10% increase also observed in the 20 and 320 mg/kg-day groups. Similarly, the relative kidney weights in females were significantly increased at 80 mg/kg-day (9%, p < 0.05). Absolute kidney weights in males were increased by 10% or more in the 80 and 320 mg/kg-day groups, but the changes were not statistically significant. Relative kidney weights were significantly increased in males exposed to ≥20 mg/kg-day (15%–18%, p < 0.05).

Sporadic, statistically significant changes in clinical chemistry also occurred, mainly in male rats. An increase in cholinesterase (73%) and a decrease in calcium (5%) were reported in males exposed to 80 mg/kg-day. Activated partial thromboplastin time was increased by 11%–18% in females at ≥5 mg/kg-day but did not follow a dose-response and was not accompanied by changes in platelets or prothrombin time. Total cholesterol was decreased (31%–41%) in males in all exposure groups. The biological significance of these changes in the absence of additional data is unclear.

In summary, the liver appears to be a primary target organ for PFPrA after short-term oral exposure, with male rats more sensitive than female rats. Coherent liver effects in males were reported at ≥20 mg/kg-day across organ weights, histopathology, and clinical serum markers, including dose-related increases in relative liver weights, hepatocyte lesions (mainly centrilobular hypertrophy but also some evidence of degenerative changes [slight focal necrosis]) and changes in serum markers indicative of hepatocellular/hepatobiliary injury (i.e., increased ALT and ALP).

Table 3 Available Experimental Animal Oral Toxicity Data for PFPrA

Species (Strain), Study Details | Dose (mg/kg-d) | Critical Effects | Other Effects | Reference, Confidence
Acute
No data available.
Short-term
Rat (Crj:CD [SD] IGS); 28-d; Oral gavage | 0, 5, 20, 80, 320 | Increased relative liver weight in males at ≥20 mg/kg-d, accompanied by hepatocyte lesions (primarily hypertrophy with some evidence of slight focal necrosis) and serum markers of hepatocellular/hepatobiliary injury (i.e., increased ALT, ALP) at ≥80 mg/kg-d | Decreased movement and increased salivation after treatment; increased activated partial thromboplastin time, albumin, albumin/globulin ratio, kidney weight; decreased total cholesterol, total bilirubin; increased incidence of forestomach lesions | CERI (2002c); High (https://hawc.epa.gov/rob/study/101066812/)
Subchronic
No data available.
Chronic/Carcinogenicity
No data available.
Reproductive/Developmental
No data available.

ALT = alanine aminotransferase; ALP = alkaline phosphatase.

### Other Data

Other human health relevant studies conducted on PFPrA include an Ames test to evaluate genotoxicity and a chromosomal aberration study (see Table 4). For the Ames test, a dose range finding study and a main study were conducted (CERI, 2002a). The main study included five concentrations ranging from 313 to 5,000 µg/plate with the highest dose of 5,000 µg/plate diluted for the remaining four doses with a geometric progression of two. The compound was found not to have potential for mutagenicity. In the chromosomal aberration test, Chinese hamster lung fibroblasts were exposed to concentrations of 0, 410, 820, or 1,640 µg/mL of PFPrA, and no increase was found in the frequencies of cells with total aberrations (chromatid breaks, chromatid exchanges, chromosome breaks, chromosome exchanges) using the short-term or the continuous treatment methods (CERI, 2002b). Growth inhibition tests, including concentrations as low as 6.41 µg/mL, demonstrated some inhibition at the 1,640 µg/mL concentration using the short-term method and at concentrations ≥205 µg/mL in the continuous treatment method, but no increases in structural or numerical aberrations.

Table 4 Summary of PFPrA Genotoxicity Studies

Endpoint | Test System | Concentrations Tested | Results Without Activation^a, b^ | Results With External Activation^a, b^ | References
Ames Assay (revertant colonies) | Salmonella typhimurium (TA100, 1535, 98, 1537), Escherichia coli (WP2 uvrA) in the presence and absence of metabolic activation system (S9 mix) | 0, 313, 625, 1,250, 2,500, 5,000 μg/plate | − | − | CERI (2002a)
Chromosomal aberration | Chinese hamster lung fibroblasts with or without S9 mix | 0, 410, 820, 1,640 μg/mL | − | − | CERI (2002b)

a Results reported as − = negative.