# METHODS

For this assessment, the general systematic review steps common to other assessments (e.g., in Integrated Risk Information System [IRIS]) were applied, including the development of populations, exposures, comparators, and outcomes (PECO) criteria for inclusion and literature search and screening of multiple databases for relevant articles.

Briefly, methods used here are consistent with the ORD Staff Handbook for Developing IRIS Assessments (Version 2.0, referred to as the draft “IRIS Handbook”) (U.S. EPA, 2022b). These methods were reviewed by the National Academy of Sciences (NASEM, 2021, 2018) and used in other peer-reviewed systematic reviews (Yost et al., 2019; Radke et al., 2018). The purpose of this human health assessment is to develop scientifically supported chronic toxicity values, where data are available. Less emphasis is placed on providing definitive judgments of the integrated weight of evidence.

The systematic review methods used to collect epidemiological and toxicological evidence for PFPrA are described in detail in Carlson et al. (2022) and Radke et al. (2022)^3^, as well as Appendix A. PFPrA was included in the list of 150 PFAS described in those materials, and for the purposes of this summary, the PFPrA-specific results found were isolated as a result of the outlined processes. In addition to database searches, nonconfidential business information (non-CBI) industry studies were identified that included toxicological evidence for PFPrA. Since February 2020, EPA has requested, pursuant to section 308 of the Act, 33 U.S.C. § 1318, that 3M provide information on its use and possible release of certain PFAS, such as PFPrA. Under that agreement, 3M shared internal files of memos, reports, interim or final data summaries or studies, correspondence, etc. that included non-CBI content for PFPrA. The available information for PFPrA received from 3M was screened for relevance to the PECO criteria (see Figure 1). Literature identified as relevant from the database searches or non-CBI data repositories underwent data extraction and study evaluation (see documentation in Health Assessment Workspace Collaborative [HAWC]: https://hawcprd.epa.gov/assessment/100500281/).

3 A literature search update has been conducted for PFPrA in December 2021 for the purposes of this assessment since the publication of the evidence map; therefore, the literature search and screening results presented here may differ from those described in Carlson et al. (2022) and Radke et al. (2022).